# Appendix H - Federal Resource Panel

- John J. Ambre, M.D., Ph.D.
- Director
- Department of Toxicology and Drug Abuse
- American Medical Association

- Bertha Atelzick
- Director
- Agency for Health Care Policy and Research

- Amy C. Barkin, M.S.W., M.P.H.
- Policy Analyst
- Office of National Drug Control Policy
- Executive Office of the President

- Andrea G. Barthwell, M.D.
- Medical Director
- Interventions
- Chicago, Illinois

- Susan L. Becker
- Director
- Division of State Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration

- Raul E. Cuervo-Rubio, M.D.
- Medical Advisor
- Center for Substance Abuse Prevention
- Substance Abuse and Mental Health Services Administration

- Dorynne Czechowicz, M.D.
- Assistant Director for Medical and Professional Affairs
- Medical Affairs Branch
- Division of Clinical Research
- National Institute on Drug Abuse

- Agnes H. Donahue, D.D.S., M.Sc.D., M.Ph.H.
- Executive Director
- Office on Women's Health
- Office of the Assistant Secretary for Health
- U.S. Public Health Service
- U.S. Department of Health and Human Services

- Murray E. Durst
- Manager
- Substance Abuse Programs
- National Council of Juvenile and Family Court Judges
- University of Nevada

- Hope H. Ewing, M.D., M.S.Ed.
- Director
- The Born Free Project
- Department of Health Services
- Contra Costa County, California

- Loretta P. Finnegan, M.D.
- Senior Advisor on Women's Issues
- Center for Substance Abuse Prevention
- Associate Director for Medical and Clinical Affairs
- National Institute on Drug Abuse
- Glen Fischer
- Program Director
- The Center for AIDS and Substance Abuse Training

- Laurie Foudin, Ph.D.
- Health Scientist Administrator
- Division of Basic Research
- National Institute on Alcohol Abuse and Alcoholism

- Susan Galbraith
- Legislative Representative
- Legal Action Center

- Al Getz
- Public Health Advisor
- Division for State Programs
- Center for Substance Abuse Treatment

- Rosemarie Henson, M.S.S.W., M.P.H.HIV Program Manager
- National Center for Chronic Disease Prevention and Health
- Promotion Centers for Disease Control

- Warren W. Hewitt, Jr.
- Special Assistant to the Director
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration

- Helen V. Howerton, M.A.
- Director
- Strategic Planning and Special Initiatives
- Office of Policy, Planning, and Legislation
- Administration for Children and Families
- Department of Health and Human Services

- Ellen Hutchins, M.S.W., M.P.H.
- Social Work Consultant
- Maternal and Child Health Bureau
- Health Resources and Services Administration

- Jag H. Khalsa, Ph.D.
- Pharmacoepidemiologist
- Division of Epidemiology and Prevention Research
- National Institute on Drug Abuse

- Virginia Z. Kucera, M.A.
- Director
- Division of Chapter Services
- American Academy of Pediatrics

- Anna Marsh, Ph.D.
- Chief
- Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment

- Janet L. Mitchell, M.D., M.P.H.
- Chair
- TIPs Project
- Chief of Perinatology
- Department of Obstetrics and Gynecology
- Harlem Hospital Center Harlem
- New York City

- Mark Parrino, M.P.A.
- President
- American Methadone Treatment Association, Inc.

- Jay Paulsen, M.D., M.P.H.
- Associate RHA for Clinical Affairs
- U.S. Public Health Service
- Region X
- Seattle, Washington

- Warren H. Pearse, M.D.
- Executive Director
- American College of Obstetricians and Gynecologists

- Herbert B. Peterson, M.D.
- Chief
- Women's Health and Fertility Branch
- Division of Reproductive Health
- Center for Chronic Disease Prevention and Health Promotion
- Centers for Disease Control

- Elizabeth Rahdert, Ph.D.
- Research Psychologist
- Treatment Research Branch
- Division of Clinical Research
- National Institute on Drug Abuse

- Pamela Stratton, M.D.
- Special Assistant for Obstetrics
- Pediatric, Adolescent, and Maternal AIDS Branch
- Center for Research for Mothers and Children
- National Institute of Child Health and Human Development
- National Institutes of Health

- Richard Strauss
- Program Analyst
- Medicaid Bureau
- Health Care Financing Administration

- Katrina Williams, M.S.W.
- Clinical Social Worker
- National Association of Black Social Workers
- Columbia Hospital for Women
- Washington, D.C.