# Appendix G - Cost Factors

## Cost Factors in the Diagnosis, Assessment, and Treatment of Drug-Exposed Infants

### Background

Determining the cost of providing treatment to drug-exposed infants is perhaps as complicated as the treatment itself. With an infinite variety of clinical, financial, and data collection issues involved, it would be futile to attempt to attach monetary values to the many services, procedures, and tests necessary to provide care to this ever-increasing segment of the population. Prior attempts by various researchers to estimate costs, both on the national and patient levels, are only rough estimates. Consequently, the following discussion focuses on the issues involved in making cost estimates, mainly by recognizing that provider charges, or pricing, bear a direct relationship to cost.

Specifically, the most intensive component of the cost of treatment is the inpatient setting. It is this treatment phase for drug-exposed infants that is emphasized here. The purpose of this information is to provide guidance to State alcohol and drug abuse directors, treatment program directors, facility financial personnel, and neonatal intensive care unit (NICU) department chiefs for developing procedures dealing with pricing, cost finding, and budgeting. Included is the following information:

- An overview of factors influencing provider pricing;
- Strategies in evaluating provider charges and costs for the treatment of drug-exposed infants;
- A listing of the most frequent services, procedures, and tests utilized in providing neonatal treatment to drug-exposed infants; and
- Sample ranges of charges obtained from hospitals that provide Level II and III NICU treatment for drug-exposed infants.

An in-depth analysis of the medical management of the drug-exposed infant, as prescribed by the consensus panel, has resulted in a breakdown of treatment into three areas:

- Evaluation and management services
- Clinical procedures
- Pathology and laboratory tests.

These areas of treatment are further delineated into individual services, procedures, and tests as defined by the American Medical Association's Current Procedural Terminology (CPT). For each item, CPT-4 codes are supplied to assist with planning for the utilization, frequency, and accurate billing of treatment. Due to changes and updates in CPT coding from 1992 to 1993, both years' CPT-4 codes are provided.

Because of dynamic changes in treatment for drug-exposed infants, and the enormity of the costs of care - both immediate and long-term - a tremendous burden is carried by provider facilities to manage costs and pricing. The rapid growth in the numbers of drug-exposed infants, coupled with the current uncertainty of health care reform, will require difficult decision-making by providers, third-party payors, and Federal and State governments. Ultimately, success in treating drug-exposed infants will be determined by these sectors of the health care industry.

### Factors Influencing Provider Pricing

When examining the various services, procedures, and tests in the TIP from a pricing perspective, it is evident that a wide variety of factors influence provider charges. Understanding these factors is crucial in attempting to identify costs, or to evaluate pricing for a particular treatment program for drug-exposed infants.

Several major factors influence provider pricing:

Clinical Intensity - Pricing is influenced by the type of patient (severity), the type of NICU (such as, Level II or III), and the patient's diagnosis and prognosis.

Volume of Services - Hospitals develop pricing for specific units or departments with an assumption about the volume of services that each department will generate. Accordingly, departments that project low utilization often have high average charges. Conversely, departments with longer lengths of stay and projections of higher volumes may have low average charges.

Charge Development Methodologies - Many hospitals use charge development methodologies that are designed to achieve a wide variety of facility-specific financial objectives. For example, facilities may want to subsidize losses in one department with profits from another, or subsidize bad debt and charity care with revenues from other payors. Competition within the hospital market, based on price or the degree of managed care penetration, can also influence prices. Additionally, a third-party payor mix will also impact pricing of provider services.

Input Costs - Providers have wide differences in the level of their input costs which, in turn, affect their prices. The costs of labor and supplies can be substantially different, even among hospitals that are in the same area.

Organizational Structure - Many hospital providers have developed into complex entities that consist of multiple related facilities integrated into a network. Accordingly, charges may be influenced by multiple market areas or entities. Specific charges may include an administrative or a technical fee. Additionally, the frequency of charges from a variety of provider entities is to be considered. Moreover, some organizations use an all-inclusive rate concept that may cause room rates to be artificially high when compared to an organization that has an "unbundled" fee structure.

Cost Data - There is a wide variation in the quality of hospital cost information that supports price setting. Some providers have sophisticated cost finding and charge development systems, while others have very basic systems. Additionally, there are a wide variety of methodologies available within the more complex systems.

Some or all of the above factors may affect a provider's charges. It is important to identify the factors that may affect any charges being evaluated in order to make informed judgements regarding the pricing of services, procedures, and tests involved in the treatment of drug-exposed infants.

### Strategies in Evaluating Provider Pricing and Costs for Treatment of Drug-Exposed Infants

Previously, several major factors that influence provider charges were identified. Below are considerations and strategies for evaluating prices and costs of treatment.

When evaluating provider prices, it is necessary to understand the degree of competition in the particular market area, prices as well as the degree of inclusiveness of the prices obtained. Do prices include room rates, professional care, or ancillary tests? Are ancillary tests charged separately? By whom? Do tests and procedures include a professional physician component? If not, how are they charged? If so charged, how much is included in the price for that component? These are just a few of the questions that should be asked to help understand pricing.

With regard to evaluating costs in order to provide care to drug-exposed infants within a hospital department, it is practical to apply a "cost-to-charge" ratio to the average daily room rate for these infants. Most facilities are able to estimate average daily NICU room rates, which are then multiplied by the hospital or department cost-to-charge ratio. Cost-to-charge ratio represents the relationship of the facility's total costs to total charges.

Example Average Daily Room Rate#151;$1,800 Cost-to-Charge Ratio - 70% Estimated Daily Room Cost - $1,260

Due to the inherent complexities in estimating the specific costs of providing care to drug-exposed infants within a given program, this crude calculation, coupled with similar estimates for ancillary treatment, is a starting point for program evaluation. Unquestionably, the multitude of factors affecting provider pricing will further influence such calculations in many ways. An advantage of this exercise is the insight gained by comparing prices and cost-to-charge ratios for similar facilities within a given market.

Setting charges for new programs and revising existing program charges will require market comparisons. As may be expected, cost-to-charge ratios fluctuate dramatically among facilities and markets, but ratios in the 65 to 80 percent range are not uncommon. This information is available in most areas of the country through various public databanks. Specific provider data may be obtained through the Federal Medicare program.

Due to the general lack of information regarding costs and charges for the treatment of drug-exposed infants, the evaluation process for treatment programs requires a thorough understanding of many quantitative and nonquantitative factors. In view of the intensive costs - in relation to potential reimbursement - for drug-exposed infants, both existing and start-up treatment programs should emphasize the comprehensive evaluation of both pricing and costs.

### Neonatal Services, Procedures, and Tests for Drug-Exposed Infants

The treatment of a drug-exposed infant encompasses a broad continuum of comprehensive services that begin during neonatal care, through the infant and toddler stages, to aftercare during the pre-school years, and possibly during later developmental phases of childhood. The purpose of Tables A, B, and C is to delineate only the evaluation and management services, clinical procedures, and pathology and laboratory tests that may be used to treat drug-exposed infants through 18 months of age. Infants will require services, procedures, or tests only as necessitated by the individual diagnoses and case complexities. The services, procedures, and tests contained in the exhibit are directly linked to the treatment of these infants (not the mother), particularly the medical management of the drug-exposed infant.

Table A: Evaluation and Management Services

Table A Evaluation and Management Services
1992 CPT-4 Code | 1993 CPT-4 Code | Description
99203 | 99203 | Office/outpatient visit, new patient, includes detailed history and exam; medical decision making of low complexity
99204 | 99204 | Office/outpatient visit, new patient, includes comprehensive history and exam; medical decision making of moderate complexity
99205 | 99205 | Office/outpatient visit, new patient, includes comprehensive history and exam; medical decision making of high complexity
99211 | 99211 | Office/outpatient visit, established patient, minimal problem(s)
99212 | 99212 | Office/outpatient visit, established patient, problem focused history and exam; straightforward medical decision making
99213 | 99213 | Office/outpatient visit, established patient, problem focused history and exam; medical decision making of low complexity
99214 | 99214 | Office/outpatient visit, established patient, problem focused history and exam; medical decision making of moderate complexity
99215 | 99215 | Office/outpatient visit, established patient, problem focused history and exam; medical decision making of high complexity
99233 | 99233 | Subsequent hospital care per day, to include a detailed interval history; detailed exam; medical decision making of high complexity
99238 | 99238 | Hospital discharge day, management
99254 | 99254 | Initial inpatient consultant for new or established patient which requires a comprehensive history & exam; medical decision making of moderate complexity
99255 | 99255 | Initial inpatient consultant for new or established patient which requires a comprehensive history & exam; medical decision making of high complexity
99281 | 99281 | Emergency department visit which includes a problem focused history and exam; straightforward medical decision making
99282 | 99282 | Emergency department visit which includes an expanded problem focused history and exam; medical decision making of low complexity
99283 | 99283 | Emergency department visit which includes an expanded problem focused history and exam; medical decision making of low to moderate complexity
99284 | 99284 | Emergency department visit which includes a detailed history and exam; medical decision making of moderate complexity
99285 | 99285 | Emergency department visit which includes a comprehensive history and exam; medical decision making of high complexity
99291 | 99291 | Critical care, first hour
99292 | 99292 | Critical care, each additional 30 minutes
- | 99295 (b) | Initial NICU Care
- | 99296 (b) | Subsequent NICU care, per day, unstable, requires constant attention
| 99297 (b) | Subsequent NICU care, per day, vital signs stable, not seizing
99361 | 99361 | Medical conference by a physician with interdisciplinary team of health professionals or representatives of community agencies to coordinate activities of patient care (patient not present); approximately 30 minutes
99362 | 99362 | Medical conference by a physician with interdisciplinary team of health professionals or representatives of community agencies to coordinate activities of patient care (patient not present); approximately 60 minutes
99440 | 99440 | Newborn resuscitation; care of the high risk newborn at delivery, including, for example, inhalation therapy, aspiration, administration of medication for initial stabilization
Notes: a. - Prices for these services may include both facility and physician components. b. - NICU procedures (CPT-4 codes 99295, 99296, and 99297) are newly defined procedures in the 1993 AMA CPT-4 codebook, and may be added to profedssional fee charge masters.

Table B: Procedures

Table B Procedures
1992 CPT-4 Code | 1993 CPT-4 Code | Description | Range of Charges ( c )
36415 | 36415 | Routine venipuncture or finger/heel/ear stick for collection of specimen(s) | $6-$9
62270 | 62270 | Lumbar puncture | $102-$150
73092 | 73092 | Radiologic exam, upper extremity, infant, minimum of two views | $42-$150
73592 | 73592 | Radiologic exam, lower extremity, infant, minimum of two views | $42-$85
74000 | 74000 | Radiologic examination, abdomen, single anteroposterior view | $42-$188
74020 | 74020 | Radiologic examination, complete, incl. decubitus and/or erect views | $76-$237
74022 | 74022 | Radiologic exam, complete acute abdomen series | $116-$300
74150 | 74150 | CAT Scan, abdomen, without contrast | $173-574
74160 | 74160 | CAT Scan, abdomen, with contrast | $311-$714
74246 | 74246 | Radiologic exam, GI tract, upper, air contrast, w/o KUB | $127-$234
74249 | 74249 | Radiologic exam, small bowel | $140-$277
74255 | 74455 | Urethrocystopgraphy, voiding, radiologic supervision & interpretation | $127-$272
76065 | 76065 | Radiologic examination osseous survey; infant | $47-$149
76506 | 76506 | EEG | $47-$149
76536 | 76536 | Echography, soft tissues of head and neck | $79-$221
76604 | 76604 | Echography, chest B-scan, (includes mediastinum) | $65-$249
76770 | 76770 | Echography, retroperitoneal (e.g. renal, aorta, nodes), B-scan and/or real time with image documentation, with or without duplex Doppler studies | $228-$326
78704 | 78704 | Imaging renogram | $228-$326
90701 | 90701 | Immunization DTP | $10-$19
90707 | 90707 | Immunization MMR | $10-$40
90731 | 90731 | Immunization Hepatitis B vaccine | $10-$42
93000 | 93000 | Electrocardiogram; with interpretation and report | $13-$110
93307 | 93307 | Echocardiography, real-time with image documentation; complete | $68-$295
93501 | 93501 | Right heart catheterization | $762-$1,810
93503 | 93503 | Swan-Ganz | $139-$2,171
93505 | 93505 | Endomyocardial biopsy | $401-$1,000
93510 | 93510 | Left heart catheterization; percutaneous | $765-$1,900
93526 | 93526 | Combined right heart cath & retrograde left heart catheterization | $879-$2,262
93527 | 93527 | Combined right heart cath & transeptal left heart catheterization | $802-$2,262
93528 | 93528 | Combined right heart cath with left ventricular puncture | $459-$2,100
93529 | 93529 | Combined right & left heart cath through existing septal opening | $879-$2,100
Notes: c. - Sample ranges of charges obtained from hospital facility charge masters (CAUTION: Charges not obtained through statisticalsurvey andshould not be relied upon for pricing decisions.)

Table C: Pathology and Laboratory Tests

Table C Pathology and Laboratory Tests
1992 CPT-4 Code | 1993 CPT-4 Code | Description | Range of Charges ( c )
8003 | 8003 | Electrolyte tests: sodium-urine; potassium-urine; chloride-urine | $13-$31
8004 | 8004 | Electrolyte tests: CO2; sodium-blood; potassium-blood; chloride-blood | $9-$74
80031 | 80299 | Serum Dilantin levels | $20-$77
80059 | 80059 | Hepatitis panel | $57-$79
82205 | 80184 | Serum phenobarbital levels | $11-$78
81000 | 81000 | Urinalysis, with microscopy | $11-$31
81002 | 81003 | Urinalysis, without microscopy, automated | $6-$20
82310 | 82310 | Serum calcium | $9-$44
82565 | 82565 | Creatinine | $5-$43
82817 | 82817 | Gases, blood; pH, pCO2 by tonometry | $30-$112
83010 | 83010 | Haptoglobin | $21-$86
83060 | 83060 | Blood sugar (sulfhemoglobin, quantitative) | $40-$147
83755 | 83735 | Magnesium | $11-$48
84105 | 84105 | Phosphorus; urine | $9-$43
84437 | 84437 | Tyroxine; requiring elution (e.g. Neonatal) | $22-$62
84479 | 84479 | T-3 levels; resin uptake | $12-$57
84520 | 84520 | Urea nitrogen (blood BUN); quantitative | $5-$43
85025 | 85025 | CBC, automated, hemogram & Platelet count | $9-$50
85031 | 85031 | Blood count; hemogram, manual, complete CBC | $6-$50
82730 | 85384 | Fibrinogen; activity | $16-$78
85595 | 85595 | Platelet; automated count [thrombocyte count for thromobocytosis] | $55-$26
85650 | 85650 | Sedimentation rate, erythrocyte; non-automated | $7-$35
86140 | 86140 | C-reactive protein | $5-$38
86185 | 86185 | Counterimmunoelectrophoresis, each antigen | $28-$70
86291 | 86291 | Hepatitis B surface antigen (HBsAb) | $14-$60
86317 | 86317 | Immunoassay for infectious agent antibody, quantitative [ELISA] | $40-$71
86403 | 86403 | Particle agglutination, antibody or antigen, each | $27-$45
86592 | 86592 | Syphilis test; qualitative (e.g., VDRL, RPR, ART, TPIA, TAP< TPMB, TPCF< RPCF) | $8-$27
-- | 86632 | Chlamydia, lgM | $66-$113
-- | 86689 | HTLV or HIV antibody, confirmatory test (e.g. Western Blot) | $50-$107
86312 | 86701 | HIV-1 | $20-$58
86662 | 86781 | Treponema Pallidum, confirm (eg.FTA-abs) | $19-$41
87040 | 87040 | Blood culture, bacterial, definitive; blood (includes anaerobic screen) | $25-$102
87070 | 87070 | Culture of eye drainage | $20-$76
87086 | 87086 | Urine culture; quantitative | $18-$76
87110 | 87110 | Culture, chlamydia | $28-$67
87205 | 87205 | Gram stain of eye drainage | $4-$36
87207 | 87207 | Smear, special stain for inclusion bodies or intracellular parasite (e.g. Herpes) [GIemSA stain, Tzanck test]
87252 | 87252 | Viral tissue culture inoculation and observation | $50-$160
88346 | 88346 | Direct immunoflourescent study (conjunctival scrapings of eye) | $27-$140
Notes: c. - Sample ranges of charges obtained from hospital facility charge masters (CAUTION: Charges not obtained through statisticalsurvey andshould not be relied upon for pricing decisions.)

Associated 1992 and 1993 CPT-4 codes have been provided for program directors, hospital and physician managers, and billing personnel to help project utilization, revenues, and reimbursement. Sample ranges of charges have been provided for procedures and tests, in order to illustrate the extreme variations between facilities. Ranges of charges for evaluation and management services are not listed, due to the incongruity between professional and facility fees, which depend upon the organizational structure of each individual facility.

Tables A, B, and C are intended to be used as planning tools to evaluate the variables that are involved in providing treatment to drug-exposed infants. The services, procedures, and tests listed are derived from the TIP but are not intended to be complete. The dynamic changes in diagnoses, assessment, and treatment will require individualized considerations in each case.

Ultimately, the costs of treatment for drug-exposed infants will be comprised of an aggregation of services, procedures, and tests, many of which are contained in Tables A, B, and C.

## References

Various hospitals located throughout the United States supplied specific charge data, NICU statistical data, cost-to-charge ratios, and other information relevant to this section. Confidentiality has been maintained to disassociate facility names with charge data.

Drug-Exposed Infants:.
Neonatal Intensive Care for Low Birthweight Infants:.
The Perinatal Center Directory. 1987.
Phibbs, C.S., Bateman, D.A., and R.M. Schwartz. 1991.
Phibbs, C.S., Williams, R.L., and R.H. Phibbs.
Charges for substance abuse hospitalization: Regional variations, 1990. 1991.
Kronson, M.E. 1991.