# Appendix F - Medical Glossary

Abruptio placentae : Premature detachment of the placenta from the wall of the uterus.

Alkalosis : Abnormally increased pH from respiratory or metabolic causes.

Antepartum : before childbirth.

Cardiac arrhythmias : Alterations of the heartbeat.

Cavitation : Formation of space in an organ or tissue.

Causation : Causal role.

Cerebral infarctions : Dead or diseased areas of the brain.

Chlamydia : A microorganism of the genus chlamydia.

Decreased habituation : Decreased responsiveness after a repeated exposure to a stimulus.

Echocardiography : Noninvasive diagnostic procedure for the heart involving high frequency sound waves.

Echoencephalographic : Use of ultrasound in measuring/examining the internal structures of the skull.

Encephalopathic syndrome : Condition of brain pathology.

Feeding intolerance : Inability to effectively suck, swallow or retain feedings.

Genitourinary tract : System of organs related to reproduction and the production and excretion of urine.

Hemorrhagic ischemic lesions : Caused by bleeding or reduced blood flow.

Hypermetabolic : Excessively increased metabolism.

Hyperpnea : Abnormally rapid or deep breathing.

Hyperpyrexia : Exceptionally high fever.

Hyperreflexia : Overactivity of physiological reflexes.

Hyperthyroid state : Overactive thyroid gland, causing a state of increased metabolism.

Hypertonia : Excessive tone or tension of a muscle.

Hypoxia : Too little oxygen reaching the body tissues.

Hypoxemia : Deficient oxygenation of the blood.

Intrapartum : During childbirth.

Intraventricular hemorrhage : Bleeding within a ventricle of the brain.

Ischemia : Localized tissue anemia or narrowing of arteries by spasm or disease.

Ischemic injury : Local injury caused by impaired blood flow.

Labile state : Frequently changing.

Meconium aspiration : Fetus breathing or sucking in a mass of meconium, which is usually discharged shortly after birth.

Necrotizing enterocolitis : Inflammation of large and small intestines.

Neurotoxicity : Toxicity to the nerves or nervous tissue.

Philtrum : The vertical groove on the median line of the upper lip.

Respiratory alkalosis : Alkalosis caused by excessive elimination of carbon dioxide due to a respiratory abnormality, such as hyperventilation.

Sepsis : A toxic condition resulting from spread of bacteria or their products from an infection.

Tachycardia : Relatively rapid heart action.

Tachypnea : Increased rate of respiration.

Thrombocytosis : Abnormal increase in the number of blood platelets.

Vascular : Affecting tube(s) that convey a body fluid, such as blood.

Vasoconstriction : Narrowing of blood vessels.