# Appendix D - Description of IDEA

## Description of IDEA (Individuals with Disabilities Education Act)

The following is an article by Barbara J. Smith, Ph.D., provided by the Council for Exceptional Children. Since this article was written, both the title and number of the law has changed. Although the article's "PL 99-457" is now called "IDEA," the description is still valid.

### Background

For over 20 years, the Federal government has been supporting research into the effectiveness of early intervention with handicapped and at-risk young children and their families. In addition to research studies, projects have been funded to develop model practices for effective early intervention.

These research and model development projects, along with programs such as Head Start, have proven that early intervention is effective. We know that if we provide support and services to children and families as early as the need is apparent, then: 1) the child's development will not be as delayed as it would be if left unattended until age 6 or older; 2) the stress for the family of having a handicapped child is lessened and they are able to function more productively; and, 3) because of these results, children and families are more able to contribute to their community - indeed, early intervention can prevent the need for many costly services later in life.

In recognition of the effectiveness and critical importance of early intervention, the United States Congress passed Public Law 99-457 in September, 1986.

### Overview

P.L. 99-457, the Education of the Handicapped Act Amendments of 1986, includes provisions for handicapped children of all ages, as well as for personnel and other activities. However, the most dramatic provisions of this new law relate to handicapped and at-risk children between the ages of birth and six and their families. Indeed, the law states:

"The Congress finds that there is an urgent and substantial need:

1. to enhance the development of handicapped infants and toddlers and to minimize their potential for developmental delay;
2. to reduce the educational costs to our society, including our nation's schools, by minimizing the need for special education and related services after (they) reach school age;
3. to minimize the likelihood of institutionalization of handicapped individuals and maximize the potential for their independent living in society; and,
4. to enhance the capacity of families to meet the special needs of their infants and toddlers with handicaps." Regarding young children and their families, P.L. 99-457 established two new Federal programs. One new program addresses 3- through 5-year-old handicapped children, and the other addresses handicapped and at-risk infants and toddlers from birth to age three.

### The Preschool Grant Program

First, P.L. 99-457 creates a new mandate for State education agencies to serve all three, four, and five year-old handicapped children by 1990-1991. This new preschool mandate was achieved by lowering the P.L. 94-142 mandate to age three. P.L. 94-142, the Education for All Handicapped Children Act of 1975, created a "right to education" for handicapped children between ages six and eighteen. However, to encourage States to serve children below the ages of six, Congress created the Preschool Incentive Grant in 1975, which, instead of mandating, simply provided some incentive monies. Now this "right to education" is extended to children beginning at age three.

This new Preschool Grant Program changes the old Preschool Incentive Grant in several ways - it is, in fact, a mandate, rather than an incentive, and it provides more than three times the funding for 3-5 year-olds!

### Who are the Eligible Children?

The Preschool Grant Program's purpose is to extend P.L. 94-142 rights to children from age three, including all definitions and requirements. Moreover, three, four and five year-olds are eligible for services under this new program if they are handicapped according to one or more of the P.L. 94-142 diagnostic categories: deaf, deaf-blind, hard of hearing, mentally retarded, multi-handicapped, orthopedically impaired, other health impaired, seriously emotionally disturbed, specific learning disability, speech impaired, and visually handicapped.

However, Congress made an important distinction for the preschooler: the documentation and count of children required by the Federal government from the States does not have to be by diagnostic category for this age group. This allows States to serve 3-5 year-olds without labeling them.

P.L. 94-142 was changed a second way for this age group: parental instruction is an allowable cost, rather than only services delivered directly to the child. This was in recognition of the important role parents play in the lives of preschool-aged children. Finally, P.L. 99-457 preschool services differ from school-aged requirements under P.L. 94-142 in that variations in length of day, or service model (home-based, center-based, etc.) are encouraged. Also, local education agencies are encouraged to contract with appropriate existing non-public school community preschool programs to provide a range of services and service models such as the mainstreaming opportunities offered by Head Start.

### What is Mandated?

P.L. 99-457 requires that States, through their State education agencies, participating under P.L. 94-142, ensure that they are providing a "free, appropriate, public education" to all handicapped children beginning at age three, by 1990-91. Currently, all States ensure that they are providing appropriate services, including individualized education programs (IEP), due process, least restricted environment, non-discriminatory testing, parent involvement, and support services to all handicapped children beginning at age six. About half the States currently serve three, four, and five year-olds.

### Funding Level

The Preschool Grant Program has two channels of funds: a) one for reimbursing school districts for children served in the previous year (served children); and, b) one for advance payment for the number of additional children the State reports they intend to serve the following year (unserved children).

Served children will generate up to $300 / child in fiscal year 1987; $400 / child in fiscal year 1988; $500 / child in fiscal year 1989; and $1,000 / child thereafter. Unserved children generate up to $3,800 / child until 1990, then all children generate up to $1,000 / child.

If the State does not, in fact, serve all the unserved children they intended to serve and received advanced payment for, their next year's allocation will be adjusted downward. Similarly, if the State serves more unserved than intended, the following year's allocation is adjusted upward.

### Failure to Comply

If a State does not ensure a free, appropriate, public education beginning at age three to all handicapped children by 1990-91, it will lose the following Federal funds:

- all Preschool Grant Funds;
- all P.L. 94-142 dollars that were generated by the 3-5 year-olds;
- and all grants and contracts related to preschool special education funded under the Education of the Handicapped Act discretionary programs.

### Handicapped Infants and Toddlers Program

The second landmark early intervention program established by P.L. 99-457 is the Handicapped Infants and Toddlers Program. This section of the law creates a brand new Federal program for handicapped and at-risk children from birth to age three years and their families. The Congressional purpose of this program is to provide financial assistance to States to:

1. develop and implement a Statewide, comprehensive, coordinated, multi-disciplinary, interagency program of early intervention services;
2. facilitate the coordination of early intervention resources from Federal, State, local, and private sources (including private insurers); and
3. enhance States' capacities to provide quality early intervention services.

While the infant and toddler program is voluntary for States - that is, they may elect to not participate - if a State does choose to participate, or apply for funding under this law, it must meet the requirements of the law. And, to be eligible for a grant in the fifth year, the State must assure that services are available to all eligible children.

### Eligibility

The new Infant and Toddler Program is directed to the needs of children, birth to their third birthday, who need early intervention because they

1. are experiencing developmental delays in one or more of the following areas: cognitive, physical, language and speech, psychosocial, or self-help skills; or
2. have a physical or mental condition that has a high probability of resulting in delay (e.g., Down's Syndrome, cerebral palsy, etc.) or
3. at State discretion, are at risk medically or environmentally for substantial developmental delays if early intervention is not provided.

Secondly, the infant and toddler's family may receive services under this program that are needed to facilitate their capacity to assist in the development of their child.

### States' Role

If a State applies for funds under this program, it must meet the following requirements:

### The first two years:

1. the governor has established an Interagency Coordinating Council made up of parents, providers, State agency representatives, personnel trainers, State legislature representatives, and others:
2. the governor has designated a lead agency (which may be the Interagency Coordinating Council); and,
3. the State assures that the funds will be used to plan, develop and implement Statewide services.

### The third and fourth years:

1. in addition to the requirements of the first two years, the State must assure that it has adopted a policy which contains the required components of a Statewide system, which are:
  - A definition of the term "developmentally delayed"
  - Timetables for ensuring services to all eligible children by the fifth year of participation
  - Multidisciplinary evaluations of the functioning of all eligible children and the needs of their families to assist in the development of their child
  - Provision of a written individualized family service plan (IFSP) for all children
  - Comprehensive Child Find system including a system for making referrals to providers. "Primary referrals sources" must be included - including hospitals, physicians, other health care providers and agencies, and daycare facilities
  - A public awareness program focusing on early identification
  - A central directory containing State resources, services, experts, and research and demonstration projects
  - A comprehensive system of personnel development - including training of public and private service providers, primary referral sources, as well as pre-service training
  - The system must include a single line of authority in a lead agency designated or established by the Governor to carry out: the general administration, supervision, and monitoring of programs and activities; the identification and coordination of all available resources within the State from Federal, State, local and private sources and the assignment of financial responsibility to the appropriate State agency; the resolution of State interagency disputes and procedures for ensuring the provision of services pending the resolution of such disputes; and, the entering into formal State interagency agreements that define the financial responsibility of each State agency for paying for early intervention services (consistent with State law) and include, among other things, procedures for resolving disputes
  - A policy pertaining to the contracting or making of other arrangements with local providers
  - A procedure for securing timely reimbursements of funds between State and local agencies
  - Procedural safeguards with respect to the settlement of disagreements between parents and providers, the right to appeal, the right to confidentiality of information, the opportunity to examine records, assignment of surrogate parents, written prior notices to parents in their native language, and procedures to ensure the provision of services pending the resolution of complaints
  - Policies and procedures relating to the establishment and maintenance of personnel training, hiring, and certification / licensing standards
  - A system for compiling data on the early intervention programs (may include sampling).
2. And that the Statewide system will be in effect no later than the beginning of the fourth year, except for the assurance of full service to all eligible children.

### The fifth and succeeding years:

1. The State must assure that the system is in effect and full services are available to eligible children.

Early intervention services must include, for each eligible child, a multidisciplinary assessment and a written Family Service Plan (IFSP) developed by a multidisciplinary team and the parents. Services which may be provided must be designated to meet the developmental needs of the child and be in accordance with an IFSP and may include special education, speech and language pathology and audiology, occupational therapy, physical therapy, psychological services, parent and family training and counseling services, transition services, medical services for diagnostic purposes, and health services necessary to enable the child to benefit from other early intervention services. Case management services must be provided for every eligible child and his / her parent.

All early intervention services must be provided at no cost to parents except where Federal or State law provides for a system of payments by parents, including provision for a schedule of sliding fees.

### IFSP Requirements?

The IFSP must be developed by a multidisciplinary team and contain: (a) a statement of the child's present levels of development (cognitive, speech / language, psychosocial, motor, and self-help); (b) a statement of the family's strengths and needs relating to enhancing the child's development; (c) a statement of major outcomes expected to be achieved for the child and family; (d) the criteria, procedures, and timelines for determining progress; (e) the specific early intervention services necessary to meet the unique needs of the child and family including the method, frequency, and intensity of service; (f) the projected dates for the initiation of services and expected duration; (g) the name of the case manager; and, (h) procedures for transition from early intervention into the preschool program. The IFSP must be evaluated at least once a year, and must be reviewed every six months or more often where appropriate.^ 1 ^

1 These descriptions are taken from materials provided by the Council for Exceptional Children.

### Funding Level

Congress authorized $50 million for Fiscal Year 1987, $75 million for Fiscal Year 1988, and such sums as may be necessary thereafter.

Funds are to be distributed to the States based upon the relative number of infants, birth to three, in the State compared to other States; that is, based on census, not actual, child count.

### Implications

As in all new nationwide or Statewide efforts, there are many implementation issues to solve and to discuss. P.L. 99-457 stresses the importance of a coordinated and multi-agency approach to the planning and dialogue that is necessary to implement the new early childhood initiatives. Indeed, a critical component of the new programs is the acknowledgment that a wide variety of local providers (public and private) should be contracted with in order to meet the requirements of the Act in a cost-effective way, while also providing a continuum of services to meet the individual needs of children and families. Secondly, the Infants and Toddlers Program mandates each State to establish an Interagency Coordinating Council to facilitate such a multi-agency dialogue. Interested individuals, providers, and parents have many opportunities to influence State and local implementation of P.L. 99-457. Local interagency groups should begin to discuss and plan the State and local solutions to early intervention and preschool services in their area.

At least two policy issues will dramatically influence implementation in each State, and both require input from all concerned groups. These two issues are the development of program standards and personnel standards. Each State will need to establish standards which agencies may use to evaluate appropriate placement options for children. In order to meet the wide variety of needs of children and families, these standards should be as inclusive as possible while also ensuring a high quality of service. Program standards should be developed to address the full continuum of services - from center-based specialized settings to child care and other community mainstreamed settings. Personnel standards will need to address professional and paraprofessional competencies across many disciplines. Standards should acknowledge the unique needs of the birth to five population, while also acknowledging the important role current providers play.

Creative solutions will be necessary of the population while a shortage of available personnel exists. Training new personnel and providing in-service training to current personnel who either need certification / licensing, or who need added competencies to meet the needs of very young children, will be critical. Secondly, solutions that provide the availability of integrated or mainstreamed settings will reflect what we know to be important for young handicapped children - that they have the opportunity to learn and interact with normally developing peers.

There are many models nationwide that currently address these and other issues. By working together, parents and providers can find the solutions that meet their local needs.