# Appendix A - Resources

## Information Resources on Drug-Exposed Infants

This Appendix provides a listing of resources - including national organizations, special reports, manuals, and books - with general information on drug-exposed infants. Although there are listings which are meant to be of help to professionals, many of the resources listed will assist caretakers of drug-exposed infants - including natural, foster, or adoptive parents - with parenting skills. The Appendix ends with a listing of simple, straightforward strategies and techniques for caring for young children.

## Section I: National Organizations

The following organizations can be contacted by phone or mail for an updated listing of materials or referrals. Please note that the CSAP National Resource Center listed below provides an extensive information and referral service which should be quite helpful to parents, caretakers, and others throughout the United States.

Center for Substance Abuse Treatment (CSAT). Division of State Programs, Rockwall II Building, 10th floor, 5600 Fishers Lane, Rockville, MD 20857, (301) 443-3820. CSAT publishes a range of material on AOD treatment, such as this TIP. CSAT is also the agency to contact for information on the new regulations regarding the Substance Abuse Prevention Block Grants. These regulations include important requirements relating to the AOD treatment of pregnant women and women with dependent children.

Center for Substance Abuse Prevention (CSAP) National Resource Center for the Prevention of Perinatal Abuse of Alcohol and Other Drugs: 9300 Lee Highway, Fairfax, VA 22031, (703) 218-5600 or (800) 354-8824. Commonly called the Perinatal Resource Center, this Center was established by CSAP in 1991 as a training, technical assistance, and information source for people working with the problem of AOD use and maternal and child health issues. Each of its specialized services are described below.

Information and referral services: The Center provides extensive telephone-based information and referral services to people working with the problem of drug-exposed infants. The Center publishes a quarterly newsletter and prepares resource packets and monographs on specific issues.

Perinatal Research and Education Management Information System (PREMIS): PREMIS is a state-of-the-art computer system maintained by CSAP's National Resource Center with up-to-date information on topics related to perinatal AOD use.

Community Team Training Institute (CTTI): CTTI trains interdisciplinary and interagency teams from a cross section of community-based organizations and local government agencies working on the problem of perinatal AOD use. Teams are selected through a competitive application process.

Technical assistance: The Center provides practical hands-on technical assistance to States, communities, and professionals to foster innovative prevention strategies and programs.

Children's Defense Fund: 25 E Street, N.W., Washington, DC 20001, (202) 628-8787. This organization does lobbying, research, and policy reports regarding children, especially the poor, minority, and the handicapped.

Child Welfare League of America (CWLA): 440 First Street, N.W., Suite 310, Washington, DC 20001-2085, (202) 638-2952. CWLA is a national membership organization of more than 700 public and private child welfare agencies that work with children and their families on critical issues such as child abuse, teen pregnancy, adoption, and foster care.

The Clearinghouse for Drug-Exposed Children: Division of Behavioral and Developmental Pediatrics, University of California, San Francisco, 400 Parnassus, Room A203, San Francisco, CA 94143-0314, (415) 476-9691. The Clearinghouse is a resource, referral, and information center serving at-risk children and families in the San Francisco Bay area. It also publishes information resources for people across the country. The Clearinghouse is affiliated with the Division of Behavioral and Developmental Pediatrics at the University of California, San Francisco, Medical Center, devoted to the multidisciplinary assessment and treatment of children.

The Clearinghouse provides a range of services designed to provide basic information about the effects of drug exposure on children's development so that parents, grandparents, teachers, and other caretakers can better understand how to care for these children and help them develop to their full potential.

The Clearinghouse for Drug-Exposed Children Newsletter, published quarterly, contains valuable information for parents, caretakers, and professionals, including policy updates and a list of recent articles on drug-exposed infants.

The ERIC Clearinghouse on Handicapped and Gifted Children: The Council for Exceptional Children, 1920 Association Drive, Reston, VA 22091-1589, (703) 264-9494.

Fetal Alcohol Network: 158 Rosemont Avenue, Coatesville, PA 19320-3727, (215) 384-1133. Contact Linda and Hank Will regarding monthly newsletter and parent support line; no charge to parents of child with FAS or FAE.

Institute on Black Chemical Abuse: 2616 Nicollet Avenue, South Minneapolis, MN 55409, (612) 871-7878. Request a free catalogue on numerous manuals, articles, and reports on substance abuse issues impacting the African American community.

La Leche League International: 9616 Minneapolis Avenue, Post Office Box 1209, Franklin Park, IL 60131-8209, (708) 455-7730. A worldwide organization dedicated to offering information and encouragement (through personal support) to women who want to breastfeed their babies.

March of Dimes Birth Defects Foundation: 1275 Mamaroneck Avenue, White Plains, NY 10605, (914) 428-7100. The March of Dimes is involved with the prevention and treatment of birth defects and infant mortality through education, research, and advocacy.

National Association for Perinatal Addiction Research and Education (NAPARE): 11 East Hubbard Street, Suite 20C, Chicago, IL 60611, (312) 329-2512. NAPARE is a center for research into the problems of perinatal addiction and perinatal AIDS, and the long-term outlook for infants and their families. The mission of NAPARE is to offer leadership in the development of multidisciplinary programs for the prevention and treatment of alcohol and other drug use in pregnancy. A goal of NAPARE is to provide a national network among professionals for the exchange of ideas regarding prevention and intervention.

National Black Child Development Institute: 1023 15th Street, N.W., Suite 600, Washington, DC 20005, (202) 387-1281. NBCDI is dedicated to improving the quality of life for African American children and youth, providing workshops and resources on a range of issues. Send for free catalogue of materials on a variety of subjects relating to children, drugs, parenting, and health concerns.

National Clearinghouse for Alcohol and Drug Information (NCADI): P.O. Box 2345, Rockville, MD 20852, (301) 468-2600 or (800) SAY-NO-TO (DRUGS). The National Clearinghouse is the information component of the Center for Substance Abuse Prevention (CSAP) of the U.S. Department of Health and Human Services. NCADI provides telephone-based information on many publications, organizations, and prevention activities throughout the country.

National Coalition of Hispanic Health and Human Services Organizations (COSSMHO): 1501 16th St. N.W., Washington, DC 20036, (202) 387-5000. COSSMHO is unique in its focus on the health and psychosocial well-being of Hispanic populations throughout the U.S. COSSMHO has literature and information on family-oriented health and substance abuse services throughout the country for the Spanish-speaking community.

National Coalition on Alcohol and Drug Dependent Women and Their Children: 1511 K Street, N.W., Suite 926, Washington, DC 20005, (202) 737-9122. This organization develops literature, sponsors workshops, and works to influence public policy for the prevention of drug and alcohol abuse among pregnant women.

National Committee for the Prevention of Child Abuse: 332 South Michigan Avenue, Suite 1600, Chicago, Illinois 60604, (312) 663-3520. Request a free catalogue of materials regarding a variety of issues targeted to parents, children, teachers, and treatment specialists. Materials also available in Spanish.

National Council of Juvenile and Family Court Judges (NCJFCJ): P.O. Box 8970, Reno, NV 89507, (702) 784-6012. The National Council is a membership organization of the nation's juvenile and family court judges dedicated to improving standards, practices, and effectiveness of courts having jurisdiction over children and families through continuing education programs, research, technical assistance, and publications, as described below.

Continuing judicial education: The Council offers continuing education for judges and related court personnel on issues related to juvenile and family law, conducting over 100 yearly educational programs throughout the country. The educational programs, covering topics such as child abuse and neglect and substance abuse, range in size from large conferences of more than 1,000 persons to as few as 15 judges.

Substance abuse project: In 1990 and 1991, a Forum on Drug-Exposed Women and Their Infants was cosponsored by the Council and CSAP. The final report will be available soon, with further followup reports anticipated, providing judicial response to the problems of drug-exposed infants and their mothers. The Council states that substance abuse is the underlying factor in 60 to 90 percent of all court cases referred to juvenile or family courts. Thus training programs and continuing education on this problem are a priority.

Technical assistance: The Council answers requests for information from individuals and organizations throughout the country.

Permanency Planning Project: The Council conducts programs focusing on "reasonable efforts" to prevent unnecessary out-of-home placement of abused and neglected children. The project has developed an eight-part training video notebook and library as well as a Protocol for Making Reasonable Efforts in Drug-Related Dependency Cases.

Publications: The Council publishes textbooks, monographs, and periodicals providing up-to-date judicial decisions and information on juvenile and family law concerns. The Council publishes: Juvenile & Family Court Journal (quarterly), Juvenile & Family Law Digest (monthly), and Juvenile and Family Justice TODAY (an in-house magazine).

Research: The Council's research arm, the National Center for Juvenile Justice, is located in Pittsburgh, PA.

National Commission to Prevent Infant Mortality, Switzer Building, Room 2014, 330 C Street, S.W., Washington, DC 20201, (202) 472-1364.

National Maternal and Child Health Clearinghouse (NMCHC): 8201 Greensboro Drive, Suite 600, McLean, VA 22102, (703) 821-8955 ext. 254. The Clearinghouse provides information over the phone on maternal and child health concerns, and sends out informational materials on various topics for little or no cost.

## Section II: Handbooks, Manuals, and Special Reports

Helping Children by Strengthening Families. Children's Defense Fund, 1992. Available for $6.50 from above address.

HOMEWORKS: At Home Training Resources For Foster and Adoptive Parents. Child Welfare League of America, 1991. This is a series of three "self-instruction workshops" that can be used individually or in collaboration with a social worker. Available for $9.95 each at above address or from the CWLA publishing house: CWLA j CSSC, P.O. Box 78161, Raritan Center, Parkway Edison, New Jersey 08818-7816, (908) 225-1900. The titles of the workbooks include:

- - Helping Children and Youth Manage Separation and Loss
  - Helping Children and Youth Develop Positive Attachments
  - Helping Children and Youth and Families Manage the Impact of Placement.

Children at The Front: A Different View of the War on Alcohol and Drugs. Charlotte McCullough, Child Welfare League of America, 1992. Executive Summary and entire book available from above-mentioned CWLA publishing house.

Head Start Substance Abuse Guide. Washington, DC. Available from Susan Webber, Special Assistant to the Commissioner, Head Start Bureau, Administration on Children, Youth, and Families, P.P. Box 1182, Washington, DC 20013.

Child Health Talk. National Black Child Development Institute, Quarterly newsletter (8 pages) providing practical information and guidance for parents, with a focus on health issues facing African-American children. Available for $8 per year at above address.

Recovery for the African American Family. Institute on Black Chemical Abuse. An 18-page pamphlet available for $3.50 at above address.

Substance Use in Pregnancy: Helping the Mother. Edited by Antoine K. Fomufod, MD, 1992. Howard University Hospital, Department of Pediatrics and Child Health, Howard University Hospital, 2041 Georgia Avenue, N.W., Washington, DC 20060, (202) 865-4564. Attention: Davine White. This is a 20-page handbook aimed at helping the mother.

Family Based Services: Solutions Focused Approach. Brief Family Therapy Center. Berg, Imsco K., Milwaukee, WI. This is a 169-page workbook that focuses on family preservation as a tool for comprehensive intervention.

Handle With Care: Helping Children Prenatally Exposed to Drugs and Alcohol. Villarreal, Sylvia Fernandez, MD., McKinney, LoraEllen, PhD and Quakenbush, Marcia. Available from ETR Associates, (800) 321-4407.

Guiding Our Children Beyond Risk: A Handbook for Caretakers of Prenatally Drug-Exposed Children. Clearinghouse for Drug-Exposed Children in San Francisco. This handbook is a unique resource covering a wide range of issues and written in clear concise language. It is designed to support the caretaker in understanding how to care for drug-exposed children.

Parenting and Child Services for Drug-Dependent Women in Pregnant Addicts and their Children: A Comprehensive Care Approach. Available from the New York Medical College, Center for Comprehensive Health Practice.

Today's Challenge: Teaching Strategies for Working with Young Children Prenatally Exposed to Drugs / Alcohol. Prenatally Exposed to Drugs (PED Program). Los Angeles United School District Division of Special Education.

Strategies for teaching young children prenatally exposed to drugs. Drug-Exposed Children's Committee, Hillsborough County Public Schools, Tampa, Florida.

CSAP National Resource Center for the Prevention of Perinatal Abuse of Alcohol and Other Drugs, described in Section I of this Appendix, can provide a listing of special reports and materials developed by States throughout the country on early childhood education strategies for children prenatally exposed to drugs.

## Section III: Other Resources

Safe Spaces: Drug and Alcohol Prevention Education for Special Needs and Drug-Exposed K-2 Children.
Aikens, F.R., D. Aikens, and G. Mace. 1981.
Beattie, M. 1989.Codependent No More.
Becker, K.N.To Keera with love: Abortion, adoption or keeping the baby, the story of one teen's choice.
Bigner, J. 1979.Parent-Child Relations: An introduction to parenting.
Castine, J. 1989.Recovery from Rescuing.
Covington, S., and B. Covington.Leaving the Enchanted Forest: The Path from Relationship Addiction to Intimacy.
DeRosis, H. 1974.A New Tested Method for Parenting without Guilt
Dunst, C., Trivette, C., and A. Deal. 1988.Enabling and Empowering Families.
Giersch, M. 1989.Will You Marry Me - and Be My Mom?
Gorski, T. 1989.Do Family of Origin Problems Cause Chemical Dependency
Levy, S.J., and E. Rutter. 1989.Children of Drug Abusers.
Lindsey, J.W., and C. Breller. 1991.Do I Have a Daddy - a Story About a Single Parent Child.
Lindsey, J.W., and S. McCullough. 1991.Teens Parenting - Discipline from Birth to Three: How To Parent and Deal with Discipline Problems in Babies and Toddlers
Miller, M., and T. Gorski. 1989.Family Recovery: Growing Beyond Addiction
Munsch, R. 1982.I Love You Forever.

## Section IV: Supportive Strategies in Caring for Young Children

The following guidelines were developed by Steps for Kids: A Family Recovery Outreach Training Project at Boston City Hospital in an effort to help families and educators work with young children in a way which supports the child's ability to regulate his or her own behavior.

Top Ten Interventions:

1. A structured physical environment that "speaks" to children with obvious uses for each area, gives a child many opportunities to make choices and decisions. It offers an inherent structure that provides limits and direction without direct adult intervention. Clearly identify and separate areas for eating, blocks, dramatic play, table work, and book sharing.
2. Predictable routines and consistent schedules provide external support that helps to regulate a child's internal rhythms. It leads children to feel control over their environment. They can depend on the sameness, and therefore feel safe, and will eventually be able to predict what will happen next.
3. Clear expectations and rules with appropriate and consistent consequences that are simply stated are crucial to help children internalize safe ways of acting. Simple language helps children to state the rules themselves, and helps remind adults not to go into lengthy explanations about why a certain behavior is not acceptable.
4. Plan transitions very carefully. Warn children about minor or major changes. Unexpected shifts in familiar routines can be highly stressful. Use warnings and regular rituals (ringing a bell, turning off the lights, singing a special song) to clue children in to what is happening.
5. Offer children control over parts of their day by giving them choices. They should choose an activity, which cup to use, which book to share, etc. Offering limited choices of what is acceptable in volatile situations ("You can hand your coat up yourself or I can help you") rather than getting into yes / no arguments offers children a graceful "out."
6. Use anticipatory guidance to avoid difficult situations or blowup. If you know that one child starts fights when playing in the block corner, have an adult monitor the play and point out when the child's behavior is escalating, then help the child to take a break to defuse the problem.
7. A foundation of mutual respect and celebration of each individual in your program is an important part of healthy self-esteem. Tell children about the wonderful things they do - praise their actions, describe when they rise to a challenge, and share your pride, celebrate the specialness of each.
8. Frequent praise should be heard throughout the day. Each child should hear at least one compliment for his or her behavior every day. Praise effort, not just success.
9. Identify feelings verbally, with facial expressions and with gestures. Help children label how they and others are feeling, and make it clear that feeling an emotion is good and important, even if it is a hard feeling. Also help them learn that only some ways of showing hard feelings are acceptable.
10. Explain how a child's actions affect other people. Help children describe their feelings ("You can tell her that it makes you angry when she takes your truck") and model your own reactions ("When you throw sand, I feel scared that you will hurt someone's eyes, you need to stop!").

Some behavioral signs that indicate decreased self-regulation skills in preschoolers:

1. Inability to make or sustain eye contact when it is culturally appropriate.
2. Perseverative "circling" around a room, or rapid motion without productive exploration of the environment.
3. An increased pitch of voice with words or nonverbal utterances such as screaming and screeching.
4. Inability to focus for more than 30 seconds on a toy.
5. Excessive movements of arms and legs when seated at a table (constant fidgeting).
6. Difficulty sitting for group activities even with a mat or adult lap.
7. Excessive temper tantrums.
8. Frequent aggressive behavior directed at oneself or others.
9. Severely limited tolerance for frustration.
10. Excessive focus on one repetitive activity, which inhibits appropriate exploration.
11. Distress with transitions.
12. Atypical body postures (head averted away, fingers splayed out, rigid body position, etc.)
13. Increased respiration rate.
14. Quick to "blow up" or "fall apart" with any stress.

All children may display one or some of these behaviors at times. Children who exhibit these behaviors frequently, to the point that the behaviors disrupt their own and other's learning, may have decreased self-regulation skills.