# A Review of the Literature

## Overview

This literature review is part of the Substance Abuse and Mental Health Services Administration’s (SAMHSA’s) Treatment Improvement Protocol (TIP) 49, Incorporating Alcohol Pharmacotherapies Into Medical Practice. Developed by a panel of experts for SAMHSA’s Center for Substance Abuse Treatment (CSAT), the TIP can assist physicians and other medical professionals in providing pharmacologic treatment, combined with psychosocial therapy, for patients who are alcohol dependent, both in primary care settings and in specialized substance abuse treatment settings.

TIP 49 focuses on the best currently recognized clinical practices for the medical maintenance of patients with alcohol use disorders (AUDs), using the four medications (disulfiram, oral naltrexone, injectable naltrexone, and acamprosate) approved by the U.S. Food and Drug Administration (FDA) for this purpose. The TIP presents best practices according to the scientific literature and the clinical experts who developed the TIP. This literature review emphasizes recent research published from 2000 to 2007 but also includes classic research studies published before 2000.

## Introduction

Recently, much new scientific knowledge has emerged concerning how pharmacotherapy can treat individuals who are alcohol dependent. Physicians can prescribe four FDA-approved medications to dampen craving, reduce heavy drinking, or promote abstinence. These medications have a mild to moderate effect and do not work for all individuals, but this first wave of effective, evidence-based medication treatments for alcoholism is at the forefront of a Government push to develop even more powerful medications. Research on pharmacotherapies for alcohol dependence is a top priority of the National Institutes of Health, which funds 68 grants totaling more than $26 million annually on medications that target the multiple neurotransmitter systems implicated in alcohol addiction (Johnson et al., 2005). Several promising drugs are in development, supported by the National Institute on Alcohol Abuse and Alcoholism (NIAAA).

For years, medications have been used primarily as an adjunct to psychosocial treatment in specialized treatment settings. With newer medications now available (naltrexone and acamprosate), interest is increasing in whether primary care physicians in routine medical practice can successfully treat with FDA-approved medications individuals who are alcohol dependent. Recent research indicates that such treatment by mainstream medical practitioners appears promising. Project COMBINE (Combining Medications and Behavioral Interventions), a recent comprehensive, well-designed NIAAA clinical trial, was carried out at 11 academic sites in the United States with nearly 1,400 patients with alcohol dependence; this project explored a variety of treatment methods—alone and in combination—in the context of low-intensity medical management (Anton et al., 2006). Alcohol consumption decreased by 80 percent over a 4-month treatment period, which suggests that medical management by primary physicians in routine practice can be a benefit in treating AUDs (Kranzler, 2006).

Emerging developments in the pharmacologic treatment of AUDs offer a significant opportunity for physicians to integrate the management of substance use disorders into primary health care. Practitioners in medical settings can add pharmacotherapies to their interventions with patients who drink heavily or are dependent on alcohol. This literature review provides resources for practitioners. Using medications to treat AUDs concerns practitioners for the following reasons:

- Up to one-half of patients with AUDs relapse shortly after detoxification and psychosocial or behavioral treatment (Johnson & Ait-Daoud, 2000). Research shows that existing approved pharmacotherapies reduce craving and help from 20 to 50 percent of patients reduce their heavy drinking and promote abstinence. When combined with primary care and psychosocial therapy, medications can effectively help many patients reduce their substance use or attain abstinence.
- Only 3 to 13 percent of patients in treatment receive naltrexone (Mark et al., 2003a). Pharmacologic treatment is grossly underused because few physicians know about these medications—or about the research showing their efficacy. The information in this literature review can assist mainstream physicians in learning about the efficacy of medications and may promote the medications’ effective use in patients who could benefit from pharmacotherapy.

Practitioners should note that patients need some level of psychosocial intervention in addition to pharmacotherapy—a consistent finding across both European and U.S. research.

## Recent Pharmacological Advances

Advances in the neurobiology of addiction and improved methodology for clinical trials have recently increased the state of knowledge about pharmacotherapies for addiction. Every 3 years, the Mesa Grande project reviews clinical trials on a variety of approaches for treating AUDs. In the 2002 update, this project added 59 new controlled trials. Based on clinical trials, this review lists the most effective treatment approaches. In 2002, for the first time, two pharmacologic therapies appeared on this list. Therapies with acamprosate and naltrexone were rated third and fourth in effectiveness among 46 treatment modalities that had 3 or more studies; these pharmacotherapies were rated behind only brief intervention and motivational enhancement, which were rated first and second (Miller & Wilbourne, 2002).

The effectiveness of the new medications reflects the findings from preclinical studies, which have exploded our knowledge about the behavioral and biological underpinnings of alcoholism (Johnson & Ait-Daoud, 2000). There have been numerous advances during the past two decades in understanding the mechanisms underlying substance dependence disorders. It is now known that alcohol-seeking behavior and drinking are influenced by multiple neurotransmitter systems, as well as by neuromodulators, hormones, and various intercellular networks (Litten, Fertig, Mattson, & Egli, 2005). The multiple neurotransmitter systems implicated in addiction include dopamine, serotonin, gamma‐aminobutyric acid (GABA), glutamate, and opiate systems. This means that researchers, in focusing on the biological systems underlying the disease, now have multiple potential targets for developing medications to treat substance dependence. Some promising directions of current research include the following:

- Applying pharmacogenetic techniques to the field of addiction. Some patients may possess a biological predisposition to the disease. These biologically vulnerable people may benefit from specific medications targeted toward ameliorating or correcting the underlying abnormalities.
- Learning about which subgroups of people may respond most positively to particular medications.
- Determining optimal dosage ranges and combinations of treatments—both combinations of medications and types and levels of psychosocial treatment—most likely to benefit particular groups based on their different biologies. Because medications are aimed at different neurotransmitter targets associated with addiction, combinations of pharmacological agents may have a synergistic effect.

Over the last decade, pharmaceutical companies have invested significant resources in studying and developing new formulations (Kenna, McGeary, & Swift, 2004b). In 1994, naltrexone became available for AUD treatment in the United States, and acamprosate became available in 2004. In addition, extended-release injectable naltrexone was approved by FDA on April 13, 2006, and became commercially available on June 13, 2006. Several review articles summarize the pharmacotherapy underlying these new medications and future therapies (Johnson & Ait-Daoud, 2000; Kenna, McGeary, & Swift, 2004a, 2004b; Kreek, LaForge, & Butelman, 2002; Mann, 2004; Myrick & Anton, 2004).

## Updated Findings From the Literature, October 2007

This online pharmacotherapy literature review, which covers articles published between 2000 and April 2007, is updated at 6-month intervals. This section describes findings from the latest update and primarily covers materials published from May through October 2007. This update identified 7 additional articles on alcohol pharmacotherapy published in 2006, as well as 37 new research articles published in 2007. Many of these articles make a significant contribution to existing knowledge. Three predominant themes are evident in this latest update of the literature:

1. The search found an unusually large number of comprehensive reviews on the current state of knowledge regarding pharmacotherapy for AUDs. The purpose of many of these reviews is to educate primary care physicians about current pharmacotherapies and to stimulate their interest in treating patients with AUDs. A recent editorial in JAMA reflects this effort to convince psychiatrists and other physicians to add medications for alcohol dependence to their continuum of care (Willenbring, 2007).
2. Several articles reflect the effort to fill in gaps in existing research knowledge—especially to cast light on which subgroups of patients will benefit most from which combinations of therapies. Some of these articles present a secondary analysis of data from large randomized controlled studies, in which the new analysis shows medication effectiveness with specific subgroups of patients in the trials.
3. The latest literature also demonstrates the ongoing surge in the number of clinical trials aimed at testing promising new pharmacotherapies for the treatment of alcohol dependence, as well as refining the use of current medications.

Much work is still needed to identify which subtypes of individuals with alcohol dependence will benefit most from a particular type of medication. Furthermore, the subtype response to a particular medication may also depend on the stage of illness at which such a person enters treatment (Ait-Daoud, Malcolm, & Johnson, 2006).

Typologies of individuals with alcohol dependence. One approach used by researchers to improve medication efficacy is to identify alcohol-dependent subtypes who may respond preferentially to a particular medication. Although a standardized typology has not been established, two frequently used typologies are (1) early- versus late-onset alcohol dependence and (2) Type A versus Type B groupings. The Type B alcohol-dependent subgroup, as characterized by Babor and colleagues (1992), includes an early age of onset of alcohol problems, high severity of dependence, polydrug use, a high degree of concomitant psychopathology, and a poor prognosis after alcohol treatment. In contrast, Type A individuals with alcohol dependence can be characterized by a late onset of problem drinking and such features as few childhood risk factors, low severity of alcohol dependence, little drug use, few alcohol-related problems, little concomitant psychopathology, and a relatively promising prognosis with traditional alcohol treatment. The Type A group is highly heterogeneous and is therefore susceptible to further subdivisions based on other features.

Genetic subtypes. Another rich current area of research aims to identify genetic variants that may modify the effects of various medications in specific subgroups of people with alcohol dependence. The gene coding for the μ opiate receptor (i.e., OPRM1) gene is a current target of interest, primarily to identify a genetic marker for subgroups that are most likely to respond to naltrexone treatment.

### New Review Articles on Pharmacotherapy for Alcohol Dependence

The recent literature includes a number of review articles that may be helpful to practitioners. In “A Rational Approach to the Pharmacotherapy of Alcohol Dependence,” Petrakis (2006) reviews the neurobiology of alcohol dependence and relates this understanding to how pharmacologic interventions can effectively address three important clinical stages in the development and maintenance of alcohol dependence. These three stages are (1) the transition between initiation of alcohol use and the start of heavy drinking, (2) the cessation of heavy drinking in individuals who want to quit, and (3) the prevention of relapse in individuals who have initiated abstinence but struggle with craving or the desire to resume alcohol use. Petrakis (2006) concludes that the best strategy in the pharmacotherapy of alcohol dependence ultimately may be based on the targeted use of medications that act on the various neurotransmitters associated with different stages of alcohol dependence.

A second overview article discusses the preclinical and clinical pharmacology of alcohol dependence, covering the most recent developments in alcohol pharmacology (Tambour & Quertemont, 2007). This article focuses on the neurobiological basis of medications for treating alcohol dependence, including promising drugs now in preliminary clinical studies.

In addition, four other reviews cover specific aspects of the pharmacotherapy of alcohol dependence. These articles include the following:

1. A review of key studies on treating alcohol dependence published between 2005 and 2006, particularly randomized controlled trials (Assanangkornchai & Srisurapanont, 2007). In terms of pharmacotherapies, the authors conclude that (1) recent studies show naltrexone has the most consistent effect in reducing alcohol consumption in the context of behavioral therapy and (2) topiramate is the only new medication on the horizon that has demonstrated effectiveness for treating alcohol dependence (Assanangkornchai & Srisurapanont, 2007).
2. A summary and review of the clinical experiences reported in the literature on the four current FDA-approved medications for treating alcohol dependence—disulfiram, naltrexone (oral and injectable forms), and acamprosate (Rosenthal, 2006). This article describes the clinical use and evidence of clinical efficacy for each medication and discusses more recent trends in combination therapies. Rosenthal (2006) also briefly discusses promising future pharmacotherapies for treating alcohol dependence, including serotonergic medications, anticonvulsants, and antipsychotics.
3. A comprehensive review of the research on medication and psychosocial treatments for those dually diagnosed with a substance-related disorder and one of the following: depression, anxiety disorder, schizophrenia, bipolar disorder, severe mental illness, or nonspecific mental illness (Tiet & Mausbach, 2007). The authors identified 59 studies, including 36 randomized controlled trials, and found existing treatments that effectively reduce substance use also decrease substance use in patients who are dually diagnosed. Tiet and Mausbach (2007) also concluded that research is urgently needed on the topic of alcohol dependence and co-occurring mental disorders, because the current status of the literature is so poor.
4. A comprehensive review of research into drug pharmacotherapies, particularly single-drug therapies, for treating common dual substance abuse and dependence disorders (Kenna, Nielsen, Mello, Schiesl, & Swift, 2007) This article covers the neurobiology and existing research on numerous approved and off-label medications for treating alcohol dependence combined with cocaine, nicotine, and opioid use disorders. The review finds strongest support for the use of disulfiram to treat co-occurring alcohol and cocaine dependence and for topiramate to treat co-occurring alcohol, nicotine, and cocaine dependence (Kenna et al., 2007).

### New Findings on Disulfiram

Two new studies report finding that disulfiram compares favorably in effectiveness with other pharmacotherapies for patients with alcohol dependence. Both studies involve subjects who were voluntarily seeking treatment.

#### Medication combined with brief, manual-based intervention therapy

Researchers in Finland have found disulfiram to be superior to both naltrexone and acamprosate in the first randomized comparison of disulfiram, naltrexone, and acamprosate with brief, manual-based intervention therapy (Laaksonen, Koski-Jännes, Salaspuro, Ahtinen, & Alho, 2007). This open-label, naturalistic trial, which took place at six different alcohol treatment and healthcare units, involved 243 Caucasian subjects who met the International Statistical Classification of Diseases and Related Health criteria for alcohol dependence; the subjects were voluntarily seeking treatment. Patients visited a physician at scheduled intervals during two phases that lasted 52 weeks; about 67 weeks after completing the study, patients were contacted for followup information—a total of 2.5 years after starting the study. This study experienced a low rate of dropout (25.1 percent after 12 weeks and 51.8 percent by the end of the 52-week study period).

During the Phase 1 continuous medication period (weeks 1–12), patients designated a contact person to be responsible for supervising and controlling their daily study medication. Patients were randomly assigned to receive (1) 50 mg of naltrexone once a day, (2) 666 mg of acamprosate 3 times a day or 1,333 mg/day for those weighing less than 60 kg, or (3) 100–200 mg of disulfiram once a day or 2 tablets (400 mg) twice a week. At regular visits throughout the 52 weeks, patients brought in a diary of their alcohol consumption and medication intake and also used a manual with homework based on cognitive-behavioral principles. During the Phase 2 targeted medication period (weeks 13–52), patients were asked to take a daily medication dose in any “craving situation” when they perceived their propensity to drink was high. During this targeted medication phase, the study center no longer provided free medication.

The main conclusion of this study was that all three medications—disulfiram, naltrexone, and acamprosate, combined with brief manual-based intervention extended over time—significantly reduce heavy drinking, reduce craving for alcohol, and increase the quality of life. However, disulfiram was superior to the other medications, especially during the continuous medication period. The study data show that, during Phase 1, disulfiram was significantly better than naltrexone and acamprosate as follows:

- In time to first heavy drinking day—46.6±27.5 days for disulfiram versus 22.0±22.0 for naltrexone and 17.6±22.0 for acamprosate:
- In time to first drink—30.4±27.8 days for disulfiram versus 16.2±20.2 for naltrexone and 11.4±17.0 for acamprosate
- In average weekly alcohol intake (g/ethanol per week)—52.0±90.7 for disulfiram versus 183.7±174.1 for naltrexone and 203.2±180.2 for acamprosate.

During Phase 2, the targeted medication period, there were no significant differences among the three medication groups on time to first heavy drinking day or in days to first drinking. Average alcohol consumption in all groups remained significantly below the baseline. However, those in the disulfiram group had significantly more abstinence days than those in the other two groups.

#### Medication for patients with co-occurring alcohol dependence and depression

Petrakis and colleagues (2007) conducted a secondary analysis of 139 male veterans with alcohol dependence and current major depression, assessing the effectiveness of naltrexone and disulfiram in this population. As in their original large-scale study comparing naltrexone and disulfiram among 254 male veterans who had alcohol dependence and comorbid mental disorders (Petrakis et al., 2005), they found no advantage of one medication over the other. In comparison with outcomes found in the original study, a person’s having a diagnosis of co-occurring depression had no significant effect on retention in treatment or on drinking outcomes, including maximum consecutive days of abstinence, percentage of heavy drinking days, or abstinence throughout the entire study period. Petrakis and colleagues (2007) concluded that both disulfiram and naltrexone are safe pharmacotherapeutic agents for treating alcohol dependence in dually diagnosed individuals with depression.

As in the original study, an unexpected finding was that patients with depression who received disulfiram reported lower craving over time than subjects with depression who received naltrexone (Petrakis et al., 2007). (For additional information on this study, see New Findings on Combined Medication Therapy below.)

### New Findings on Oral Naltrexone

#### Effects of patient compliance on outcomes

Research suggests that the effectiveness of naltrexone in clinical trials—and probably also in clinical treatment—can be greatly influenced by the subjects’ adherence to the medication. A new study reanalyzed data, expanding the variable drinking outcomes reviewed, from an alcohol treatment trial involving 160 participants (Anton et al., 2005). This reanalysis looked specifically at how much patient compliance with naltrexone influenced the outcomes and compared two methods for measuring compliance (Baros, Latham, Moak, Voronin, & Anton, 2007). The researchers conclude that, because patient adherence to naltrexone has such a large influence on treatment outcomes, practitioners need to give utmost attention to methods for enhancing their patients’ compliance. The article also summarizes evidence from the literature on strategies to use for improving compliance (Baros et al., 2007).

This study evaluated outcomes for 137 randomized patients with alcohol dependence who completed 12 weeks of naltrexone or placebo, combined with either cognitive-behavioral therapy (CBT) or motivational enhancement therapy (MET). Compliance was monitored and compared using urine riboflavin measurements during study weeks 2, 6, and 12, as well as a medication event monitoring system (MEMS) that provided a detailed computerized record of when patients opened their medication bottles. Findings included the following:

- Accounting for adherence and compliance with naltrexone changed the outcomes (not significant in the original study) to demonstrate a significant drug therapy interaction for percentage of days abstinent, number of heavy drinking days, or total standard drinks.
- MEMS and urine riboflavin measures of compliance provided similar estimates of treatment effectiveness, although combining these two measures yields the most conservative, stringent index of medication compliance.
- The size of the treatment effect approximately doubled in the most compliant individuals.
- Patients treated with naltrexone and CBT showed more days of abstinence, less relapse to heavy drinking days, and fewer total drinks than the other groups (those receiving naltrexone plus MET or placebo plus psychotherapy).
- Older age predicted pill-taking compliance.

#### Effects of naltrexone on specific subgroups or populations

The treatment effects of naltrexone have recently been examined in several alcohol-dependent subgroups, including (1) those with a family history of alcohol problems and/or antisocial traits, (2) individuals with at least one copy of the G allele of the OPRM1 gene, and (3) women, including those with a comorbid eating disorder.

1. Family history of alcohol problems and/or antisocial traits Prior research has suggested that naltrexone may be significantly more effective in moderating heavy drinking among patients with certain characteristics, including a family history of drug problems, early onset of alcohol problems, high degree of antisocial traits, and comorbid drug use. Rohsenow, Miranda, McGeary, & Monti (2007) tested the contribution of these factors to naltrexone effectiveness by reanalyzing data from 128 patients with alcohol dependence enrolled in a 12-week, double-blind clinical trial of naltrexone. Participants in the original study had been recruited from a substance abuse day treatment program (Monti et al., 2001). Findings of the reanalysis included the following:
  - Having a high percentage (at least 20 percent) of first- and second-degree family members with problem drinking significantly affected naltrexone’s effects, resulting in lower drinking rates among those patients
  - Having more antisocial traits resulted in less heavy drinking on naltrexone than on placebo when the patient took at least 70 percent of the medication, whereas more socialized patients had no benefit from naltrexone regardless of compliance (degree of socialization was measured using the California Personality Inventory Socialization scale).
  - Age of onset of alcohol problems and comorbid cocaine or marijuana use had no interaction effect with the medication.
2. This study suggests that a meaningful (and inexpensive) way to match patients to naltrexone is by identifying those who have 20 percent or more relatives with alcohol problems and/or have high antisocial scores. Patients with alcohol dependence who use marijuana or cocaine can also be benefited by naltrexone.
3. Effects of naltrexone on alcohol sensitivity and genetic modulators of medication response. To better understand naltrexone’s mechanisms of action, particularly its effects on alcohol sensitivity and craving in persons with the A118G single nucleotide polymorphism (SNP) of the OPRM1 gene, Ray and Hutchison (2007) studied naltrexone’s effects in a within-subject, double-blind, placebo-controlled laboratory trial. Naltrexone was found to blunt alcohol’s effects on subjective feelings of stimulation, positive mood, craving, enjoyment, and vigor. This study suggests that, during treatment with naltrexone, carriers of the A118G SNP (the G allele) experience a more pronounced reduction in alcohol reward than others, which may explain the lower relapse rate with naltrexone treatment in these individuals. Naltrexone’s dampening of the rewarding subjective effects of alcohol may thus reduce the likelihood that a slip will trigger a full-fledged relapse into heavy drinking for carriers of the G allele.
  This laboratory study tested the effects of naltrexone in 40 subjects who drank heavily (15 of whom had at least one copy of the G variant and 25 who were homozygous for the A allele) after a 5-percent ethanol solution was infused intravenously. Findings included the following:
  - Naltrexone was differentially effective based on the individual’s genotype; it significantly reduced the self-reported, alcohol-induced high in participants with at least one copy of the G allele but had no effect on participants who were homozygous for the A allele.
  - After taking naltrexone, subjects with the G allele demonstrated greater blunting of the alcohol-induced high when the breath alcohol concentration (BrAC) reached 0.06 mg/L, with greatest effects at highest BrAC. This suggests that the effects of naltrexone may be alcohol-dose dependent (Ray & Hutchison, 2007).
4. Effects of naltrexone on women who are alcohol dependent. Relatively little is known about the efficacy of naltrexone for treating women who are alcohol dependent. The Women’s Naltrexone Study investigated the safety and efficacy of naltrexone combined with cognitive-behavioral coping skills therapy (CBCST) in 103 women who are alcohol dependent, 29 of whom had comorbid eating pathology (O’Malley et al., 2007b). Participants were randomized to receive weekly group CBCST plus either naltrexone (50 mg) or placebo for 12 weeks.
  This study, which essentially measured the added effect of naltrexone over CBCST, found no significant differences between naltrexone and placebo on the primary study outcomes: time to first drinking day, time to first day of heavy drinking, or percentage of participants who continued to meet criteria for alcohol dependence. It should be noted that all groups in this study showed large improvements in drinking behavior: overall, the percentage of days abstinent during treatment more than doubled from baseline, and the number of drinks during drinking day decreased from 7.12 drinks at baseline to 1.83 drinks during treatment. However, positive outcomes specifically with naltrexone included the following:
  - Naltrexone significantly delayed the time to second and third drinking days for women who did not maintain abstinence from alcohol.
  - Symptoms of eating pathology decreased during treatment among all groups (e.g., the frequency of binge eating decreased by almost 70 percent). This suggests that treatment for alcohol dependence may be associated with improvements in eating pathology (O’Malley et al., 2007b).
5. The outcomes of this study have been reexamined in a reanalysis of the data, described in the following study.

### Reanalysis of Negative Trials of Naltrexone

Novel approaches to data analysis may help resolve the current heterogeneity of clinical findings about naltrexone’s efficacy in treating alcohol dependence. Most clinical trials show naltrexone to be effective in delaying relapse to heavy drinking, reducing the intensity of drinking, or increasing the percentage of days abstinent—usually with a small to moderate effect size. However, several randomized trials have found no significant benefit associated with naltrexone treatment. Gueorguieva and colleagues (2007) reanalyzed two such negative trials: a large Veterans Affairs (VA) clinical trial (Krystal, Cramer, Krol, Kirk, & Rosenheck, 2001) and the Women’s Naltrexone Study described above (O’Malley et al., 2007b). The researchers used a trajectory-based approach—previously untried in alcohol treatment studies—to look at naltrexone efficacy by evaluating patterns of drinking rather than single events or summary measures. Findings were as follows:

- Based on the data, three distinct trajectories of daily drinking over time (both for any drinking and for heavy drinking) could be modeled using a semiparametric group-based approach. These trajectories were similar for both studies and consisted of (1) “abstainer,” (2) “sporadic drinker,” and (3) “consistent drinker.”
- Compared with those on placebo, subjects on naltrexone were significantly more likely to be abstainers or sporadic drinkers rather than consistent drinkers.
- Naltrexone doubled the odds of following the “abstainer” trajectory instead of the “consistent drinker” trajectory.
- Medication compliance had a significant effect on the trends over time, decreasing the odds of drinking in all trajectories.

The authors suggest that trajectory-based statistical methods could play a role in the future analysis of clinical trials. This method can be used to estimate empirically the heterogeneity in the study population and to identify subgroups with similar response patterns for whom treatment is effective.

### New Findings on Extended-Release Injectable Naltrexone

Researchers have conducted a secondary analysis to show the efficacy of extended-release, injectable naltrexone (XR-NTX) among a subgroup of patients enrolled in a 6-month, multicenter, randomized, double-blind, placebo-controlled trial that was previously reported in the literature (O’Malley, Garbutt, Gastfriend, Dong, & Kranzler, 2007a). The original study (Garbutt et al., 2005) found that 380 mg (the approved dose) per day of XR-NTX, combined with 12 sessions of psychosocial therapy, was significantly more effective than placebo in reducing the rate of heavy drinking among patients with alcohol dependence who had been abstinent for 7 or more days before receiving their first injection.

The question addressed in this new data analysis is, “How effective is XR-NTX among patients who had been abstinent for as few as 4 days before receiving the first injection?”—a practical issue in U.S. detoxification settings, where detoxification commonly takes 4 days (O’Malley et al., 2007a). Of 624 patients with alcohol dependence in the original study, 82 patients—the subjects of this analysis—had been voluntarily abstinent for 4 days or more before treatment started. To be eligible for the study, patients had to have had at least two episodes per week of heavy drinking (5 or more drinks per day for men and 4 or more drinks for women) in the 30 days before enrollment. O’Malley and colleagues (2007a), who analyzed the data on a wide range of drinking-related outcomes, concluded that a long period of pretreatment abstinence is not required to achieve positive outcomes among patients receiving monthly 380 mg injections of XR-NTX. The data showed that XR-NTX prolongs abstinence and reduces the number of both drinking days and heavy drinking days in patients who are abstinent for as few as 4 days before starting treatment. For these patients, the analysis showed the following:

- Their rate of abstinence throughout the entire 6-month study was nearly 3 times higher than in patients on placebo.
- Their median time to first drink was 41 days compared with 12 days for those on placebo.
- Their rate of continuous abstinence at the end of the study was 32 percent, compared with 11 percent for those on placebo.
- Their median time to first heavy drinking event was 9 times longer than median time for those on placebo (more than 180 days compared with 20 days).
- Their median number of drinking days per month decreased by 90 percent, totaling 0.7 days per month versus 2.9 days for those on placebo.
- Their median number of heavy drinking days per month decreased by 93 percent, totaling 0.2 days versus 2.9 days for those on placebo.

Responders to treatment were defined as patients who had no more than 2 heavy drinking days in any consecutive 28-day period. Among patients who abstained for as few as 4 days before receiving 380 mg of XR-NTX, 70 percent were classified as responders, more than twice as many as the 30 percent of responders on placebo. Consistent with these observed reductions in drinking, the XR-NTX treatment was associated with greater reductions in gamma glutamyltransferase (GGT) levels over time compared with placebo.

The analysis also looked at patients who received a 190 mg dose of XR-NTX. Their drinking-related outcomes generally fell in an intermediate range between those of patients receiving a 380 mg dose and those on placebo, suggesting a dose-response effect.

### New Findings on Acamprosate

A brief article on acamprosate reported on a previously unknown finding—three case studies of patients with long-standing alcohol dependence who had primitive reflexes that continued throughout detoxification but were completely resolved within 24 hours after initiation of acamprosate (Guzik, Bankes, & Brown, 2007). These male patients presented with the primitive snout (sucking motion) reflex and/or the grasp reflex, both of which are highly unusual in healthy adults. Primitive brain-stem reflexes are suppressed after infancy; the presence of these reflexes in adults connotes systemic, metabolic, or neurologic disease that impairs the brain’s ability to suppress them. Guzik and colleagues (2007) suggest that acamprosate (at 666 mg 3 times daily) may resolve the primitive snout and grasp reflexes—a neurological finding that suggests cognitive impairment—among patients with alcohol dependence.

Primitive reflexes can be readily identified in a physical examination, and their potential value in staging various illnesses and assessing prognosis is just beginning to be studied (Guzik et al., 2007). Research is needed to determine whether monitoring primitive reflexes in patients with alcohol dependence before and after initiation of therapy with acamprosate could help identify their potential treatment responses and prognoses. This study also suggests that acamprosate may reduce the cognitive impairment that interferes with early-stage recovery for some patients who are alcohol dependent.

### New Findings on Combined Medication Therapy

#### Combining naltrexone and disulfiram for patients with co-occurring alcohol dependence and depression

Petrakis and colleagues (2007) concluded that the combined use of naltrexone and disulfiram offered no advantage over either medication alone for subjects who are alcohol dependent with co-occurring major depression. This secondary analysis of data from a large randomized controlled trial looked at 139 male veterans who were alcohol dependent with a Diagnostic and Statistical Manual of Mental Disorders (American Psychiatric Association, 1994) diagnosis of current major depression. These subjects represented 54.7 percent of the 254 participants in the original study of veterans with alcohol dependence and comorbid mental disorders (Petrakis et al., 2005).

This secondary analysis showed that subjects with current co-occurring depression achieved positive outcomes comparable to all subjects in the trial—a trial in which almost 70 percent of subjects achieved complete abstinence during the 12-week study period. In addition, on the Hamilton Depression Rating Scale, these subjects with depression also showed a significant decrease in depression from baseline to posttreatment. Side effects of the combined medications, as well as naltrexone and disulfiram alone, were tolerated and consistent with those seen in patients who do not have a dual diagnosis. Because there was no advantage to the combined medication or to one pharmacotherapeutic agent over another, the choice of medication to treat AUDs in patients with depression can depend on such factors as patient preference (Petrakis et al., 2007).

#### Combining medication with psychosocial treatment

In a review article designed for physicians, Weiss and Kueppenbender (2006) describe the significant advances made in the development, standardization, and rigorous testing of the psychotherapeutic approaches used to treat alcohol dependence. Medical management interventions are available to physicians, as are strategies for improving medication adherence. The authors discuss the evidence from the literature since 1984, particularly clinical trials, on the interactions and efficacy of disulfiram, oral naltrexone, and acamprosate with particular psychosocial treatments. Weiss and Kueppenbender (2006) recommend that physicians use these medical management techniques when prescribing pharmacologic agents to patients with alcohol dependence. They also recommend that physicians become knowledgeable about the various psychotherapies as background for referring their patients who are alcohol dependent to concurrent psychosocial treatment. Some of the conclusions made by Weiss and Kueppenbender (2006), based on their review of the literature, include the following:

- Adding medical management therapy and pills to a specialty psychosocial therapy improves outcomes for patients who are alcohol dependent.
- Psychosocial interventions, ranging from brief medical management to more intensive manual-based psychotherapies, have all been shown to produce positive outcomes in certain studies, depending on the specific medication and the study context.
- No evidence suggests that one single form of psychosocial treatment is a criterion standard for patients with alcohol dependence who receive pharmacotherapy.
- For disulfiram, a successful and promising adjunctive approach is behavioral marital therapy augmented with a disulfiram contract by the couple.
- For naltrexone, the evidence suggests (although not conclusively) that CBT may be particularly effective as adjunct therapy.
- For acamprosate, few studies have been done in combination with structured, controlled psychosocial interventions. The limited evidence suggests that acamprosate may be used equally effectively with a variety of psychosocial treatments and that little psychosocial treatment may be needed beyond medical management.

Building on the existing literature about psychosocial approaches combined with pharmacotherapy, two recent articles describe additional possible psychotherapy approaches to augment the medication. The proposed therapies, described below, include (1) the trial of a second-generation CBT combined with oral naltrexone and (2) the use of contingency management (CM) with medications for treating substance abuse.

Broad-spectrum treatment (BST). A 3-month, randomized controlled trial explored whether a broad-spectrum CBT would be more effective than MET for patients who are alcohol dependent treated with naltrexone (Davidson, Gulliver, Longabaugh, Wirtz, & Swift, 2007). This initial trial suggests that, at least when combined with naltrexone, a second-generation CBT may have a meaningful clinical advantage over brief interventions such as MET (Davidson et al., 2007).

This research group developed a unique CBT manual-based protocol for alcohol dependence that combined components of the three psychotherapies demonstrated to be effective in NIAAA’s Project MATCH: CBT, 12-Step facilitation, and MET. This new BST approach incorporates such content material as cognitive restructuring, drink refusal, and assertiveness training with a patient-specific selection of session modules. The treatment matching uses a decision tree, with modules tailored for the individual through a psychometric assessment of each patient’s need.

In this study, 149 patients with alcohol dependence were randomly assigned to receive either BST and naltrexone or MET and naltrexone. Patients who received BST had a significantly higher percentage of days abstinent than patients receiving MET. Treatment was tailored in response to an assessment of the patients’ psychosocial resources, and the differential advantage for BST was most marked for those patients with social networks that supported drinking.

Contingency management. Clinical trials have demonstrated the effectiveness of CM procedures—an approach in which patients receive concrete rewards or reinforcers for discrete targeted behaviors. However, few trials have assessed the value of CM procedures when combined with pharmacotherapy for alcohol dependence. Carroll and Rounsaville (2007) review the existing evidence and suggest that CM would be an ideal platform for addressing the weaknesses of many pharmacotherapies used to treat drug abuse. CM can directly reinforce medication adherence, which may substantially improve compliance in treatment where unpleasant side effects must be overcome or where compliance is not strongly reinforced by rapid benefits from the treatment itself. The authors describe a variety of CM strategies used to improve compliance with disulfiram among patients with alcohol dependence.

A recent pilot double-blind trial of memantine—a selective noncompetitive N-methyl-D­aspartate (NMDA) receptor antagonist—among 34 individuals with alcohol dependence did not support the use of memantine for treating patients who are actively drinking. However, this study did support the use of voucher incentives to facilitate retention. With voucher incentives for clinic attendance, 80 percent of subjects completed the 16-week trial (Evans, Levin, Brooks, & Garawi, 2007).

### New Findings on Promising Drugs

In a review of the evidence supporting use of medications for alcohol withdrawal and dependence, Ait-Daoud, Malcolm, and Johnson (2006) discuss clinical trial findings on naltrexone and acamprosate but focus particularly on anticonvulsants. The article presents the neurochemical rationale and research evidence supporting use of anticonvulsants, particularly carbamazepine, valproate, and topiramate, for treating alcohol dependence. On the basis of controlled trials to date, the authors conclude:

- Valproate may be a promising medication for treating patients who are alcohol dependent with a comorbid bipolar disorder.
- Topiramate, a potent novel anticonvulsant, offers promising evidence of being a safe and effective option for the pharmacological treatment of alcohol dependence, warranting further study.
- Anticonvulsants such as valproate and topiramate may offer the advantage of being single medications that can be used from detoxification through the treatment process—being used first to treat the acute withdrawal symptoms and then, once abstinence has been achieved, to prevent relapse by modulating postcessation craving and affective disturbance (Ait-Daoud, Malcolm, & Johnson, 2006).

#### Topiramate

Recent research shows that topiramate, a drug with complex actions that include activity at the GABA and glutamate receptors, is a promising treatment for alcohol dependence. Although only two major studies have been conducted, the consistency and size of topiramate’s clinical efficacy suggest the need for further research, particularly on the most efficacious ceiling dose, the impact of longer periods of treatment, and the subtypes of alcoholism most benefited by treatment with topiramate (Johnson et al., 2007).

A 17-site, double-blind, placebo-controlled trial with 371 men and women who were alcohol dependent found that up to 300 mg per day of topiramate reduced the percentage of heavy drinking days from baseline to week 14 and produced significant and meaningful improvement in a wide variety of self-reported drinking outcomes (Johnson et al., 2007). Topiramate compared with placebo treatment was associated with a significantly higher rate of achieving 28 or more days of continuous nonheavy drinking and 28 or more days of continuous abstinence. Furthermore, using two different analytic approaches, the topiramate group reached 28 or more days of continuous abstinence significantly faster than the placebo group (Johnson et al., 2007). Topiramate also decreased plasma GGT in the heterogeneous and graphically diverse population. These positive findings replicated the results of a smaller, randomized controlled trial (Johnson et al., 2003b). Topiramate’s therapeutic effect was evident no later than week 4. At the end of the 14-week trial, differences between topiramate and placebo were still increasing, suggesting that even more improvement may occur with longer administration (Willenbring, 2007).

Two additional factors make topiramate seem particularly promising for treating alcohol dependence in primary care settings. First, topiramate proved effective with patients who were actively drinking rather than abstinent at the time medication was started. Patients in the multisite study were drinking heavily at the time of enrollment and study randomization (men were drinking 35 or more and women 28 or more standard drinks per week). These patients were not required to stop drinking before entering the study, although they had to express a desire to stop or reduce their consumption of alcohol with the possible long-term goal of abstinence. Second, the study provided only minimal behavioral support that focused on enhancing medication compliance and encouraging abstinence—a brief intervention that could be provided by nonspecialist health practitioners (Johnson et al., 2007).

At least 10 percent of participants reported adverse events; the events reported most by those on topiramate, as compared with placebo, included paresthesia, taste perversion, anorexia, difficulty with concentration and attention, and pruritus (Johnson et al., 2007). In the multisite study, where topiramate was titrated over a 6-week period, the attrition that was due to adverse events was 18.6 percent for the topiramate group and 4.3 percent for controls. In the earlier study (Johnson et al., 2003a), where adverse events were similar but titration occurred over a longer, 8-week period, retention rates for the topiramate and control groups were similar. However, in the multisite study, the researchers found that completion rates approached 90 percent among practitioners experienced in administering topiramate, whereas less experienced practitioners had more difficulty with retention. To enhance adherence, the authors advise clinicians to use a slow titration schedule over 8 weeks and to provide focused education for patients on how to manage emergent adverse events (Johnson et al., 2007).

The efficacy of topiramate was also supported in the following two small studies:

- Topiramate as add-on therapy for patients with alcohol dependence who do not respond to standard treatment. In an observational open-label, multisite study in Spain, 64 patients who were alcohol dependent with poor outcomes in standard treatment were provided with a mean dose of almost 200 mg per day of topiramate and monitored over a 12-month period (Fernández Miranda et al., 2007). The addition of topiramate resulted in a significant decrease in all outcomes measured—number of drinking days per month and standard drinking units consumed per day, craving, priming, dependence intensity scales, and serum transaminase levels.
- Ability of topiramate to increase periods of continuous “safe” drinking (defined by NIAAA as 1 or fewer standard drinks per day for women and 2 or fewer standard drinks per day for men). Some patients with alcohol dependence do not achieve abstinence during treatment. Researchers carried out a secondary analysis of data from a double-blind, randomized, controlled 12-week trial (Johnson et al., 2003b) to determine whether topiramate recipients were able to achieve longer continuous periods of “safe” drinking than those on placebo (Ma, Ait-Daoud, & Johnson, 2006). The analysis found that soon after topiramate was administered, recipients began to achieve increasing lengths of “safe” drinking relative to placebo. Furthermore, these early treatment gains appear to be predictive of continuing improvement as the length of time in treatment increases (Ma et al., 2006).

#### Other medications under development

In addition to topiramate, the 2007 literature search identified positive reports on controlled clinical trials of two potential medications for treating alcohol dependence: (1) nalmefene, an opioid antagonist, and (2) quetiapine, an atypical antipsychotic that targets both dopamine and serotonin receptors. Findings were as follows:

- Targeted nalmefene. A multisite, randomized double-blind study in Finland found that 10 to 40 mg doses of nalmefene were safe and reduced heavy drinking among 242 subjects with self-identified drinking problems (Karhuvaara et al., 2007). Subjects received minimal psychosocial intervention and took nalmefene only when drinking seemed imminent. After 28 weeks, 57 subjects on nalmefene continued into a 24-week extension period with randomization to continued nalmefene or placebo. Decrease in drinking was significantly greater for subjects on nalmefene than on placebo, which was corroborated by significant decreases in alanine aminotransferase and GGT. During this randomized withdrawal period, subjects remaining on nalmefene maintained the drinking level achieved in the initial 28 weeks, whereas those switched to placebo seemed to return to more frequent heavy drinking.
- Quetiapine. According to a double-blind, placebo-controlled 12-week trial among 61 subjects who were alcohol dependent, quetiapine (400 mg per day) may be more effective in treating people with the more severely affected Type B alcoholism compared with those with Type A alcoholism. This small study found a significant interaction between quetiapine and alcoholic subtype (Kampman et al., 2007). As predicted, Type B subjects treated with quetiapine had significantly fewer days of drinking and fewer days of heavy drinking than Type B subjects on placebo. Compared with those on placebo, people with Type B alcoholism who were treated with quetiapine had alcohol craving significantly reduced. Among the patients with Type A alcoholism, quetiapine offered no advantage over placebo in improving drinking outcomes. Nine patients treated with quetiapine (31 percent) maintained complete abstinence compared with two patients on placebo (6 percent).

### New Findings on Pharmacotherapy Use by Medical Care Providers

Relatively few specialized addiction treatment programs use pharmacotherapies for alcohol dependence, according to recent data collected from large samples of specialty programs in the public and private sectors (Ducharme, Knudsen, & Roman, 2006). Even as evidence for the efficacy of these medications has increased, the longitudinal data in this study suggest that the proportion of treatment programs using pharmacotherapies has actually been declining over time and the number of patients who receive medications remains low. Ducharme and colleagues (2006) discuss historical patterns among addiction treatment programs, as well as the numerous structural and philosophical barriers that impede the adoption of pharmacotherapies by the specialty treatment system. This article suggests a wide range of specific environmental, funding, regulatory, and linking structures and strategies that could help reduce resistance and promote the adoption of medications in addiction treatment (Ducharme et al., 2006).

#### Attitudes of professional alcohol counselors

Community-based addiction treatment centers rarely use pharmacotherapies for treating their patients who are alcohol dependent (Thomas, Wallack, Lee, McCarty, & Swift, 2003). Before initiating pharmacotherapy education at six community-based addiction treatment centers, Thomas and Miller (2007) collected baseline data on the knowledge and attitudes of 84 counselors and administrators attending a staff education project. Respondents came only from centers that had no on-staff medical provider. The data showed the following:

- These counselors and administrators, with just one exception, had very little or no knowledge about naltrexone.
- Most believed that adjunctive pharmacotherapy is ineffectual in treating alcohol dependence.

The authors concluded that lack of knowledge and confidence about pharmacotherapy by counselors is a barrier to more widespread referral and use of pharmacotherapies in alcohol treatment centers. Focused education will be needed for both counselors and administrators.

The study suggests that educational efforts do not need to overcome negative opinions about adjunctive pharmacotherapies. Instead, the intent should be to convey accurate and empirically supported information about the value of current medications. The respondents’ personal recovery status from addiction did not appear related to their valuation of pharmacotherapies. The most senior addiction professionals—those with more than 10 years of experience in the addiction field—were generally more positive in their valuation of adjunctive pharmacotherapy (Thomas & Miller, 2007).

#### Attitudes of patients toward pharmacotherapy

A second study looked at whether medically hospitalized patients with alcohol dependence are interested in pharmacotherapy and primary care to treat their alcoholism (Stewart & Connors, 2007). This survey covered 50 inpatients identified as alcohol dependent; all were receiving internal medicine services in a university-affiliated public hospital. Most survey participants were socioeconomically disadvantaged males admitted with disorders that heavy alcohol use would typically cause or exacerbate. In the month before being admitted to the hospital, these patients on average had been drinking on 86 percent of days and had averaged 8.4 drinks per drinking day. Their responses suggest that many such patients will be interested in receiving medication for alcoholism:

- 84 percent agreed they needed to stop drinking.
- 50 percent agreed that medication helps prevent drinking.
- 66 percent agreed they would like to receive an effective medication to help prevent drinking.

Interest in receiving effective pharmacotherapy was positively associated with addiction severity, adverse consequences, recognition of the problem, and drinking frequency. The reaction to primary care was mixed; only 32 percent of these patients were interested in primary care treatment for their alcoholism. The authors conclude that primary care followup alone may not adequately address patients’ perceived needs; many patients may also require prompt referral to specialty care after hospitalization (Stewart & Connors, 2007).

## Approved Drugs for Treating Patients Dependent on Alcohol

The following review of the literature covers major research articles published between 2000 and April 2007. The focus is on drugs currently approved by FDA for treating alcohol dependence (disulfiram, oral naltrexone, long-term injectable naltrexone, and acamprosate).

### Disulfiram

The first medication for alcohol dependence, approved by FDA almost 60 years ago, is an aversive therapy still used today. Disulfiram (Antabuse®) irreversibly inhibits acetaldehyde dehydrogenase, an enzyme involved in alcohol metabolism, which leads to an accumulation of acetaldehyde. This accumulation leads to a severe reaction when alcohol is consumed. Disulfiram also inhibits dopamine β-hydroxylase in the brain and may have a direct effect on brain catecholamines. Disulfiram causes a variety of unpleasant symptoms when a person drinks alcohol, such as nausea, vomiting, hypotension, and facial flushing. Despite these reactions, approximately 15 percent of patients continue to drink alcohol while taking disulfiram (Myrick, 2002). When daily dosages of 1,000–3,000 mg were used, deaths were reported from disulfiram–alcohol reactions (Fuller & Gordis, 2004). The reasonable startup dose today is 250 mg, and, if the patient drinks and does not experience a disulfiram–alcohol reaction, the dose can be increased to 500 mg (Fuller & Gordis, 2004).

Fuller and Gordis (2004), asking “Does disulfiram have a role in alcoholism treatment today?” respond with a qualified “yes.” They conclude that the field needs to move beyond disulfiram and develop better pharmacotherapies that act on the neurobiological processes underlying alcohol dependence. Fuller and Gordis suggest that physicians do not need to prescribe disulfiram when patients first enter treatment. But if a patient is struggling to maintain sobriety, the supervised use of disulfiram is warranted (Fuller & Gordis, 2004). Side effects are usually minor; serious adverse reactions are uncommon, although the physician needs to monitor for hepatotoxicity.

#### Research on disulfiram

Research studies and clinical experience over 55 years offer valuable information about the efficacy and safety of disulfiram. Almost 40 years elapsed from the time disulfiram became available before the first multisite, randomized clinical trial covering 605 participants was published (Fuller et al., 1986). Many large double-blind studies of disulfiram show no therapeutic effect compared with placebo (reviewed by Myrick, 2002). There is still no unequivocal evidence from randomized, controlled trials to show that disulfiram improves abstinence rates over the long term (Mann, 2004).

Brewer, Meyers, and Johnsen (2000) reviewed all published clinical studies in which there had been attempts to directly supervise the administration of disulfiram at least weekly. Adequate supervision included appropriate training of supervisors and review of their ability to supervise. These researchers found 13 controlled and 5 uncontrolled studies with supervised disulfiram administration and reported positive findings in all but 1 study. In general, the better the supervision, the better the outcomes. Under supervised situations, disulfiram reduced drinking, prolonged remissions, improved treatment retention, and facilitated compliance with psychosocial interventions.

Anton (2001), in a review of the literature, concluded that the evidence for disulfiram is mixed. According to Anton (2001), the most reliable study suggests that disulfiram is not better than placebo. In the reviewed studies, Anton (2001) reported that the factors that seem to improve treatment effectiveness with disulfiram include patient motivation, patient monitoring, being an older man, and concomitant treatment with acamprosate.

The most recent comprehensive review of the literature, done by Suh, Pettinati, Kampman, & O’Brien (2006) and covering the literature from 1937 to 2005, concluded that supervised disulfiram can be an effective treatment for alcohol dependence. The reviewers recommended that more research be done on disulfiram combined with other—and especially newer—psychotherapies.

#### Disulfiram use in primary care

Adverse events. Disulfiram is well tolerated in most patients, with the most common adverse effects being tiredness, headache, and sleepiness (Chick, 1999). Toxicities such as psychotic reactions, confusional states, and neuropathy are rare and appear to be dose related (Bevilacqua, Diaz, Diaz, Silva, & Fruns, 2002; Chick, 1999).

Disulfiram hepatitis is a very rare, sometimes fatal complication that particularly affects women (Brewer & Hardt, 1999). A Danish study of adverse reactions to disulfiram over a 22-year period estimated the rate of fatal disulfiram-induced hepatitis to be 1 per 25,000 patients treated per year, with the peak of hepatotoxicity occurring 60 days after the beginning of treatment. Because hepatotoxicity can usually be reversed if disulfiram is stopped before liver disease is clinically evident, Wright, Valfier, and Lake (1988) recommend liver function testing before treatment, at 2-week intervals for 2 months, and at 3- to 6-month intervals thereafter. Chick (1999) recommends informing the patient and the patient’s family and physician of the risk and immediately stopping the drug if adverse effects, such as fever preceding jaundice, are noted. Fuller and Gordis (2004) recommend supervised administration of disulfiram, along with careful monitoring for hepatotoxicity.

Conditions excluding treatment with disulfiram. Patients with cardiovascular or cerebrovascular disease are excluded from treatment because hypotension can occur during a disulfiram–alcohol interaction (Fuller & Gordis, 2004). Disulfiram has been reported to cause fetal abnormalities, so pregnant women should not use it. Disulfiram is also contraindicated in patients who have an idiopathic seizure disorder or cannot understand the risks associated with use of the drug. Disulfiram may influence adversely the pharmacokinetics and, therefore, the effects of medications metabolized by the cytochrome p450 system, such as warfarin, phenytoin, amitriptyline, and benzodiazepines (including chlordiazepoxide and diazepam but not lorazepam and oxazepam). Disulfiram also interferes with the pharmacokinetics of the tricyclic antidepressants. Fuller and Gordis (2004) report that the literature indicates disulfiram is unsafe to use concomitantly with monoamine oxidase inhibitors.

Patients appropriate for disulfiram. Data suggest that disulfiram is most effective in older, motivated individuals and in those who are supervised during daily ingestion. Predictors of efficacy with disulfiram include patients highly motivated for abstinence, people who are married or have a good support system, people with behavioral contracts to take the medication, and people legally compelled to take disulfiram (Myrick & Anton, 2004; O’Farrell, Allen, & Litten, 1995). Disulfiram can also support abstinence when people who are alcohol dependent attend events that involve alcohol, such as family celebrations.

In general, disulfiram seems to have limited acceptance in the treatment of alcohol dependence (Anton & Swift, 2003). Several recent, small pilot studies suggest that disulfiram might be safe and useful for the following types of patients:

- Patients who are positive for the hepatitis C virus (HCV). A recent review of the literature recommends monitored disulfiram treatment for patients positive for HCV (Kulig & Beresford, 2005).
- Patients who are court ordered.Martin, Clapp, Alfers, and Beresford (2004) found that compliance with treatment was 61 percent after 18 months for those with court-ordered, supervised disulfiram treatment. This compared with 18-percent compliance among those in a voluntary, supervised disulfiram group.
- Adolescent patients. In a small, preliminary study, Niederhofer and Staffen (2003) compared 13 adolescents ages 16–19 on disulfiram with 13 controls. After 90 days, the mean abstinence duration was significantly greater for the disulfiram group than for the placebo-treated controls (68.5 days [SD 37.5] vs. 29.7 days [SD 19.0]). Disulfiram was well tolerated in adolescents, except for occasional diarrhea.
- Patients with severe mental illness. A preliminary study of 33 patients with severe mental illness and alcohol dependence found that supervised disulfiram treatment was associated with decreases in the number of days hospitalized. Controlled research is needed to evaluate the effects of disulfiram in this population (Mueser, Noordsy, Fox, & Wolfe, 2003).
- Patients codependent on alcohol and cocaine. Disulfiram’s main effects in initiating abstinence in cocaine and alcohol use were still maintained a year after patients with codependence received short-term (12-week) treatment with disulfiram combined with psychotherapy (Carroll et al., 2000). Ninety-six patients who were codependent randomly received CBT either with or without disulfiram, 12­Step facilitation with or without disulfiram, or clinical management with disulfiram. Carroll and associates (2000) concluded that this randomized controlled trial supports the efficacy of disulfiram with this challenging codependent population. The findings suggest long-term benefits can result from comparatively brief treatments that facilitate the initiation of abstinence.

#### Research needs

The effects of disulfiram on craving have not been widely studied, but disulfiram is unlikely to be very powerful in reducing craving, especially if a patient has not achieved sustained abstinence (Anton & Swift, 2003). For better information about the use of disulfiram today, randomized clinical trials need to determine whether supervised ingestion of disulfiram:

- Would be useful to ensure sobriety for such high-risk groups as criminal offenders and those who have failed previous attempts at treatment
- Is better if supervision is performed by a clinic staff member or by a relative
- Would improve treatment outcomes when combined with newer pharmacotherapies (Fuller & Gordis, 2004).

### Oral Naltrexone

In 1994, FDA approved naltrexone, an OPRM1 antagonist, as a 50 mg oral tablet for the prevention of relapse to alcohol use. Before its approval for alcohol dependence, naltrexone had been approved by FDA for use in opioid dependence. Adding alcohol treatment as an indicator for use of naltrexone was based on the results of two single-site studies that evaluated the medication as an adjunct to relapse prevention psychotherapy. These studies found that naltrexone reduced drinking frequency and the likelihood of relapses to heavy drinking (O’Malley et al., 1992; Volpicelli, Alterman, Hayashida, & O’Brien, 1992).

Naltrexone represented a new era of medications studied specifically to treat AUDs. Disulfiram’s mechanism of action centers on its use as an aversive agent, whereas naltrexone is thought to act directly on the brain as an anticraving compound (Myrick & Anton, 2004). As an opioid antagonist, naltrexone is thought to reduce the reinforcing subjective or behavioral response to alcohol (Davidson, Palfai, Bird, & Swift, 1999; Garbutt et al., 2005; McCaul, Wand, Stauffer, Lee, & Rohde, 2001). Naltrexone must be prescribed with caution because individuals abusing opioids may experience withdrawal and those receiving opioids for analgesia will find them ineffective during naltrexone treatment. Patients receiving naltrexone should carry an explanatory card to show to healthcare personnel in an emergency.

#### Research on naltrexone

In the last decade, the efficacy of naltrexone for alcohol dependence has been extensively studied, particularly in the United States. At least 19 published controlled studies of about 3,200 patients have compared the effects of oral naltrexone with placebo; nearly all showed efficacy in the treatment of alcohol dependence (Garbutt et al., 2005). The majority of clinical trials support the hypothesis that naltrexone can reduce the urge to drink, increase the number of days abstinent, and minimize the risk of relapse to heavy drinking in some patients (O’Malley & Froehlich, 2003). However, two recent studies, including a large, multisite VA study, have reported no or minimal effectiveness in reducing drinking behavior as compared with placebo (reviewed by Krystal et al., 2001). One reason for this ineffectiveness may be the high rate of noncompliance among patients in the VA study. Lack of compliance with oral naltrexone is a problem that varied greatly across studies, with 40 to 90 percent of subjects completing treatment in the studies.

The lack of consistent findings on the effects of oral naltrexone may be the result, at least in part, of variations in how compliant patients are with the medication. A number of studies indicate that poor compliance with therapy can limit the effectiveness of oral naltrexone (Johnson & Ait-Daoud, 2000; Kranzler, Wesson, & Billot, 2004). For example, in a 3-month followup study, Volpicelli and colleagues (1997) found that only patients who took their oral daily dose on at least 90 percent of study days improved their drinking outcomes. No differences were found between the placebo group and those who took naltrexone on fewer than 90 percent of study days on any drinking measure; 50 percent of these subjects relapsed, changing from abstinence to clinically significant drinking during the study. In a large, 1-year collaborative study in the United Kingdom, only patients who took at least 80 percent of their naltrexone tablets experienced better drinking outcomes than those on placebo (Chick et al., 2000). The outcomes in 17 clinical trials of naltrexone at a dose of 50 mg per day are shown in Exhibit 1 (Mann, 2004).

Exhibit 1 Published Placebo-Controlled Clinical Trials of Naltrexone 50 mg/day in Alcohol Dependence^a^

Study | Country | No. of Patients | Duration (mo) | Outcome Measure | Result^b^
Oral Naltrexone
Krystal et al., 2001 | US | 627 | 3 or 12 | TFR | No effect
Gastpar et al., 2002 | Germany | 342 | 3 | TFR | No effect
Guardia et al., 2002 | Spain | 202 | 3 | TFR | Increased
Kranzler et al., 2000 | US | 183 | 3 | TFR | No effect
Kranzler et al., 2000 | US | 183 | 3 | TFD | No effect
Chick et al., 2000 | UK | 169 | 3 | TFR | No effect
Anton et al., 1999 | US | 131 | 3 | TFR | Increased
Anton et al., 1999 | US | 131 | 3 | %DA | Increased
Anton et al., 1999 | US | 131 | 3 | DDD | Decreased
Heinälä et al., 2001 | Finland | 121 | 3 | %RHD | Reduced (CS group)
Heinälä et al., 2001 | Finland | 121 | 3 | None | No effect (ST group)
Balldin et al., 2003 | Sweden | 118 | 6 | %HDD | Reduced (CS group)
Monti et al., 1999 | US | 116 | 3 | HDD | (Decreased)^c^
Monti et al., 1999 | US | 116 | 3 | DDD | (Decreased)^c^
Monti et al., 1999 | US | 116 | 3 | None | No effect (ST group)
Morris et al., 2001 | Australia | 111 | 3 | TFD | No effect
Morris et al., 2001 | Australia | 111 | 3 | TFR | Increased
Latt et al., 2002 | Australia | 107 | 3 | %RHD | Decreased
Latt et al., 2002 | Australia | 107 | 3 | TFR | Longer
O’Malley et al., 1992 | US | 97 | 3 | TFR | Increased (CS group)
O’Malley et al., 1992 | US | 97 | 3 | None | Increased (ST group)
Volpicelli et al., 1997 | US | 97 | 3 | TFR | Increased in compliant patients
Volpicelli et al., 1992 | US | 70 | 3 | TFR | Increased
Hersh et al., 1998 | US | 64^d^ | 2 | TFD | No effect
Oslin et al., 1997b | US | 44 | 3 | %RHD | No change
Injectable Naltrexone
Kranzler et al., 1998 | US | 20 | 2 | %HDD | Reduced

a Studies are ranked by size.

b The results of the studies are identified as“ increased” or “decreased” only when the intergroup difference was statistically significant at the level of 0.05.

c Positive results were obtained in this study only once the 40 noncompliant patients were excluded from the analysis.

d This study was performed in patients with concomitant alcohol and substance abuse.

CS = coping skills training.

DDD = drinks per drinking day.

HDD = heavy drinking days.

ST = supportive therapy.

TFD = time to first drink.

TFR = time to first relapse.

% DA = percentage of days abstinent.

% HDD = percentage of heavy drinking days.

% RHD = percentage of patients relapsing to heavy drinking.

Reprinted with adaptations from CNS Drugs, 18(8), 490, 2004, with permission from Wolters Kluwer Health.

The extensive research on oral naltrexone has produced numerous review articles and several meta-analyses of the literature. Three meta-analyses concluded that the effect of naltrexone is significantly greater, on average, than that of placebo (Kranzler & Van Kirk, 2001; Srisurapanont & Jarusuraisin, 2005; Streeton & Whelan, 2001). The meta-analysis by Streeton and Whelan (2001) found that, after 12 weeks of naltrexone treatment, patients experience significantly fewer episodes of relapse and significantly more remain abstinent compared with subjects on placebo. The meta-analysis by Srisurapanont and Jarusuraisin (2005), which covered 3,048 subjects in 27 randomized controlled trials from 34 published and unpublished papers, concluded the following:

- Short-term treatment. Naltrexone should be accepted as a short-term treatment for alcoholism. In comparison with placebo, short-term treatment significantly reduces the chance of alcohol relapse for 36 percent of patients, is likely to reduce the chance of returning to drinking for 13 percent, and can lower the risk of withdrawing from treatment for 28 percent of patients.
- Medium-term treatment. Medium-term naltrexone treatment gives no benefit over placebo in terms of relapse prevention, but it does increase the time to first drink and diminishes craving. In this regard, naltrexone plus intensive psychosocial treatment is superior to naltrexone plus a simple psychosocial treatment. Naltrexone is also superior to acamprosate in reducing relapses, number of drinks, and craving.
- Concomitant treatment strategies. To improve treatment adherence and to ensure that real-world treatment is as effective as research findings, some form of psychosocial intervention and management of adverse effects needs to accompany naltrexone therapy.
- Unanswered questions. The existing research is limited because many trials are of short duration and have small sample sizes. Important areas of concern include the lack of data on different psychosocial benefits and on how long patients who respond to naltrexone should continue their treatment. The evidence for longer term (more than 8 months) efficacy of naltrexone remains to be demonstrated (Mason, 2003).

Recently, Pettinati and colleagues (2006) reviewed all published, randomized placebo-controlled trials of naltrexone to resolve inconsistencies in naltrexone’s reported efficacy across trials. Drinking outcomes measured in these studies related to four outcomes: two pertaining to “any drinking” and two pertaining to “heavy or excessive drinking.” This review found an advantage for naltrexone over placebo in 70 percent of clinical trials that measured reductions in “heavy or excessive drinking” but in only 36 percent of trials that measured abstinence or “any drinking.” Pettinati and colleagues (2006) concluded that naltrexone’s therapeutic effects are most related to outcomes pertaining to heavy or excessive drinking.

#### Naltrexone use in primary care

Of particular interest to physicians in primary healthcare settings is one recent study that looked at whether general internists and primary care physicians, using naltrexone, could treat patients who are alcohol dependent as effectively as addiction specialists can (O’Malley et al., 2003). Results indicated that primary care counseling with naltrexone pharmacotherapy can be effective in select patients. Study subjects were recruited from newspaper ads and required to be abstinent from alcohol for 5 to 30 days before initiating treatment. In this nested sequence of randomized, placebo-controlled trials, patients received the following:

- Phase I—197 patients received 10 weeks of naltrexone and either (1) brief counseling from a primary care physician (an initial 45-minute visit followed by 15-to 20-minute sessions in weeks 1 through 4, 6, 8, and 10) or (2) CBT from an addiction specialist (an initial 1.25-hour session followed by weekly 50-minute sessions for 10 weeks).
- Phase II—Responders from both groups received 24 weeks of continuing maintenance with naltrexone.

In Phase I, the results were comparable in the two groups, with 84.1 percent of primary care patients and 86.5 percent of CBT patients avoiding persistent heavy drinking. Persistent heavy drinking was defined as more than 2 days of heavy drinking (5 or more drinks per day for men and 4 or more drinks per day for women) during the last 28 days of Phase I. In Phase II, the response to naltrexone maintenance was better maintained among those who received primary care than in those with counseling appointments (O’Malley et al., 2003). Monterosso and colleagues (2001) also found a significant advantage of naltrexone use over placebo in patients who received 12 weeks of concurrent primary counseling.

The results are available from NIAAA’s COMBINE study, a multisite, randomized, controlled trial that evaluated medical management with naltrexone, acamprosate, or both, with or without additional specialist treatment (combined behavioral intervention). Participants received interventions over a 4-month period and were evaluated for up to 1 year after treatment. Findings from this study suggest that naltrexone with medical management can be delivered successfully in healthcare settings, which would greatly expand the number of people receiving treatment (Anton et al., 2006). In fact, the COMBINE data suggest that naltrexone can be effective in the context of medical management without specialized behavioral treatment.

In the COMBINE study, participants taking naltrexone received 25 mg on days 1 through 4, 50 mg on days 5 through 7, and 100 mg on days 8 through 112. Doses were chosen based on preliminary evidence that doses higher than those commonly prescribed could be more efficacious and provide better coverage for missed doses; two pilot studies confirmed the tolerability of these doses (Anton et al., 2006). Ongoing or recurrent dose reductions could be made for individual participants and were made in 12.1 percent of patients for naltrexone, compared with 11.9 percent for acamprosate, 20.9 percent for acamprosate plus naltrexone, and 7.8 percent for placebo. On average, 88 mg of naltrexone was taken daily, and the mean medication adherence rate for naltrexone was 85.4 percent—similar to the adherence rates for those receiving acamprosate or combined behavioral interventions. The COMBINE study confirmed the efficacy of naltrexone in reducing drinking among volunteers who were newly abstinent from alcohol. Key findings included the following:

- Participants receiving naltrexone plus medical management had a higher percentage of days abstinent (80.6 percent) than those receiving placebos and medical management only (75.1 percent).
- Naltrexone reduced the risk of a first heavy drinking day over time; the reduction in risk was 0.28, consistent with meta-analyses of other naltrexone trials that used 50 mg per day and included specialist care (Anton et al., 2006).

Other findings from the COMBINE study are detailed in the sections on acamprosate and on combined medication therapy.

Adverse events. Some researchers have attributed the low degree of compliance with naltrexone to poor tolerability and hepatic toxicity (Volpicelli et al., 1997). However, a recent meta-analysis of naltrexone studies concluded that only 10 percent of patients fail to complete treatment because of one or more adverse drug effects and that hepatic toxicity is very unlikely at the current dose of 50 mg of oral naltrexone daily (Bouza, Magro, Muñoz, & Amate, 2004; Yen, Ko, Tang, Lu, & Hong, 2006). Yen and colleagues (2006) concluded that naltrexone is not hepatotoxic at the recommended daily dose and may be beneficial for patients with elevated liver enzymes. In the COMBINE study, with its higher naltrexone dosage, only 1 of 70 serious adverse events could have been related to the medication. Of the 601 participants, 12 (primarily those in the naltrexone groups) had treatment-emergent levels of liver enzymes (aspartate aminotransferase or alanine aminotransferase) greater than five times the upper limit of normal; these cases resolved once the medication was discontinued except for two cases (one participant did not return for retesting and the other continued heavy drinking) (Anton et al., 2006).

Conditions excluding treatment with naltrexone. Patients are ineligible for naltrexone if they have poor liver function or a history of liver disease, have recent prescribed or nonprescribed opioid use, and, for women, are pregnant or not using adequate birth control (Rohsenow, 2004). Absolute contraindications to naltrexone use include acute hepatitis, liver failure, active opioid withdrawal, and the current use of methadone or opioid-containing medications prescribed to manage pain and treat serious medical conditions, such as heart disease, severe arthritis, sickle cell anemia, and recurrent congestive heart failure (CSAT, 1998). A relative contraindication applies to patients who have an anticipated need for opioids to treat an identified medical problem, because use of naltrexone can impede the effectiveness of prescription and over-the-counter analgesics, cough medicines, and pain medications that contain opioids (CSAT, 1998).

Patients appropriate for naltrexone. Current research suggests that the patients most likely to benefit from naltrexone are those who have close relatives with alcohol problems, have particularly strong urges to drink, or have limited cognitive abilities (Rohsenow, 2004). Naltrexone is also well tolerated in older patients (Oslin et al., 1997a). People with lower blood concentrations of the drug may benefit from a larger dose, and those with good results on naltrexone may benefit from longer maintenance (Rohsenow, 2004).

#### Research needs

More research is needed on which subgroups of patients are most likely to respond well to naltrexone, as well as to other pharmacotherapies. In a recent controlled trial in Germany, Kiefer, Helwig, Tarnaske, Otte, and Wiedemann (2005a) looked at the response to naltrexone and acamprosate by patients who had (1) low versus high baseline somatic distress, depression, and anxiety, (2) low versus high baseline craving, and (3) typological differentiation according to the subtypes proposed by Cloninger and Lesch (Lesch & Walter, 1996). A comparison of the course of abstinence rates indicated that naltrexone was effective particularly in patients with high baseline depression, whereas acamprosate was mainly efficacious in patients with low baseline somatic distress. Baseline craving showed no predictive value. Naltrexone revealed best treatment effects in Lesch’s types III and IV typology, whereas acamprosate was mainly effective in type I (Kiefer et al., 2005a).

Some researchers hope that it may become possible to choose therapy based on identification of genetic subtypes of the specific molecular targets for drugs. For example, because a family history of alcohol problems is a predictor of naltrexone response, it is hypothesized that a gene variation of the OPRM1 may increase an individual’s susceptibility to substance dependence, as well as increase the response to naltrexone. To test this, a recent randomized study of patients with alcohol dependence examined the association between their treatment outcomes and two specific polymorphisms of the gene encoding the OPRM1. In subjects of European descent, individuals with one or two copies of the Asp40 allele who were treated with naltrexone had significantly lower rates of relapse and a longer time to return to heavy drinking than those homozygous for the Asn40 allele (Oslin et al., 2003). If these results are replicated, then gene testing may be a feasible and cost-effective way to identify individuals who are most likely to respond to naltrexone treatment.

Research by McGeary and colleagues (2006) found that, among non-treatment-seeking heavy drinkers, all of naltrexone’s moderating effects on craving and on a cue-elicited urge to drink could be accounted for by Asn40Asp polymorphisms in the OPRM1 gene. However, in a study of veterans being treated for alcohol dependence, Gelernter and colleagues (2007) found no significant interactions between the OPRM1 Asn40Asp polymorphisms and the response to naltrexone treatment. Oslin, Berrettini, and O’Brien (2006) reviewed the current research agenda and the biological correlates of the receptor genes that have been demonstrated to predict clinical response to naltrexone in individuals who are dependent on alcohol.

### Extended-Release Injectable Naltrexone

On April 13, 2006, FDA approved the marketing application of Alkermes, Inc., for its extended-release injectable form of naltrexone with the trade name Vivitrol^®^ (formerly Vivitrex^®^). Vivitrol is a once-monthly, single-dose 380 mg intramuscular injectable medication that uses a proprietary Medisorb^®^ drug delivery technology. Vivitrol became commercially available on June 13, 2006, through a limited network of specialty pharmacy providers.

A second company, DrugAbuse Sciences, also has an injectable naltrexone formulation called Naltrel in Stage III clinical trials. A third injectable formulation, Depotrex^®^, is under development.

The extended-release injectable formulation of naltrexone was developed to address the problem of compliance with oral naltrexone. The long-acting injectable formulation offers a number of advantages. An intramuscular injection is needed monthly instead of daily, which ensures that patients are exposed to the medication for at least the first month. This monthly, extended-release injection eliminates the need for daily self-dosing and reduces the opportunity for patients to discontinue their medication impulsively. Any discontinuation in therapy would come to the attention of the physician or healthcare provider who is administering the injections. The long-acting formulation also produces a more consistent and predictable drug blood level than oral naltrexone (Dunbar et al., 2006). The injectable form eliminates first-pass metabolism, while reducing the repetitive peak-to‐trough plasma naltrexone levels associated with daily oral naltrexone administration (Dunbar et al., 2006; Johnson et al., 2004).

#### Research on injectable naltrexone

Several formulations of injectable naltrexone have been tested in pilot studies and clinical trials since 1998, and all studies have shown the injectable long-acting formulation to be safe, well tolerated, and effective in reducing heavy drinking days and other measures of problem drinking. Although most studies involved small numbers of subjects, developers of the two investigational formulations have published multicenter, randomized, placebo-controlled clinical trials (Garbutt et al., 2005; Kranzler et al., 2004). Studies done to date include the following:

- Preliminary studies. In a 12-week study of an injectable naltrexone formulation (Depotrex) combined with 8 weekly coping skills sessions, the 15 patients on 206 mg of daily naltrexone had fewer drinking days than 5 patients on placebo, supporting continued research on the sustained-release drug (Kranzler, Modesto-Lowe, & Nuwayser, 1998). An 8-week study of the same injectable formulation among 12 subjects who were heroin dependent showed that both low- (192 mg) and high-dose (384 mg) injections were safe and effective and produced long-lasting antagonism to the effects of heroin (Comer et al., 2002). Few adverse effects were reported except for mild discomfort at the injection site, and blood plasma levels remained above 1 ng/ml for 3 to 4 weeks after the injection.
- DrugAbuse Sciences Naltrexone Depot Study Group. This group conducted the first multicenter study of injectable naltrexone (Naltrel) for alcohol dependence, randomly assigning 315 patients either to an intramuscular injection of naltrexone monthly for 3 months or to placebo; all subjects received five sessions of manual- guided MET (Kranzler et al., 2004). The medication was well tolerated, with approximately 74 percent of subjects receiving all injections. For those taking injectable naltrexone, there was a significant advantage over placebo in time to first drinking day, fewer drinking days during treatment, and a significantly greater abstinence rate than for the placebo group (18 vs. 10 percent). Earlier studies, including a 6-week, open-label trial of one 300 mg injection among 16 subjects, combined with weekly individual counseling sessions, found no serious adverse events and a significant reduction in the number of drinks per day, heavy drinking days, and the proportion of drinking days compared with baseline (Galloway, Koch, Cello, & Smith, 2005; Modesto-Lowe, 2002).
- Vivitrex^®^ Study Group. This group conducted a 6-month, double-blind, placebo-controlled trial of long-acting injectable naltrexone, using two different doses, at 24 U.S. public hospitals, private and VA clinics, and tertiary care medical centers. Adults who were actively drinking were randomized to naltrexone treatment or placebo, and 624 received at least one injection. All subjects received 12 sessions of a low-intensity psychosocial intervention. Compared with placebo, the high (380 mg) dose resulted in a 25-percent decrease in the event rate of heavy drinking days, whereas the low (190 mg) dose resulted in a 17-percent decrease. The long-acting naltrexone was well tolerated, and there was no evidence of hepatotoxicity (Garbutt et al., 2005). An earlier 16-week, multisite pilot study had shown the formulation to be both safe and well tolerated (Johnson et al., 2004).

#### Injectable naltrexone use in primary care

Now that it has been approved for marketing by FDA, injectable naltrexone is available as a treatment option that can be used by primary care practitioners and addiction specialists. In the multisite trial, the efficacy of the 380 mg dose was evident in the first month after the initial injection and was maintained over the 24-week treatment period (Garbutt et al., 2005). Unlike patients in the oral naltrexone trials, the majority of patients were actively drinking when they started injectable naltrexone treatment. However, the FDA Center for Drug Evaluation and Research (CDER) analysis of the study data concluded that injectable naltrexone was effective only in those who were abstinent at baseline. CDER’s analysis emphasized the proportion of patients who did not relapse to heavy drinking (FDA CDER, personal communication, 2008).

Adverse events. In patients using oral naltrexone, high urinary levels of 6-β-naltrexol have been associated with adverse events, such as headache, anxiety, nausea, and spontaneous erection (King, Volpicelli, Gunduz, O’Brien, & Kreek, 1997). In a multicenter study, at least 15 percent of individuals withdrew from oral naltrexone treatment because of adverse events, particularly nausea (Croop, Faulkner, & Labriola, 1997). In contrast to oral naltrexone, plasma levels of extended-release naltrexone remain relatively constant among patients taking the injectable formulation, which may be one reason for its milder adverse effects. The lack of first-pass metabolism with injectable formulations, with reduced levels of 6-β-naltrexol, may also contribute to its improved adverse-event profile (Johnson, 2006). The peak plasma concentration of injectable preparations exceeds that of oral naltrexone during the days immediately following the injection. The higher tolerability of injectable naltrexone may be because such peaks occur daily with oral therapy but only early in treatment with the injectable formulations (Johnson, 2006). The following side effects were observed in the clinical trials of injectable naltrexone:

- Vivitrol. High doses (400 mg) of Vivitrol seemed to be safe and well tolerated in the 16-week clinical trial, with the four most common side effects among 40 subjects being nausea, headaches, nonspecific abdominal pain, and pain at the injection site. Two subjects dropped out from adverse effects—one from induration at the injection site and one from an allergic reaction resulting in angioedema (Johnson et al., 2004). In the longer 24-week clinical trial, subjects who received the high (380 mg) dose of Vivitrol were significantly more likely to report nausea, fatigue, decreased appetite, dizziness, and pain at the injection site than those in the low (190 mg) dose or placebo groups (Garbutt et al., 2005). Among subjects in the high-dose Vivitrol group, 14.1 percent discontinued treatment compared with 6.7 percent of those in both the low-dose and the placebo groups. Two of the high-dose subjects dropped out because of serious adverse events—allergic-type eosinophilic pneumonia and interstitial pneumonia—which resolved following medical treatment. The most frequent reasons for dropping out of the study were nausea, injection site reactions, and headaches (Garbutt et al., 2005).
- Naltrel. In general, the first 12-week clinical trial showed Naltrel to be safe and well tolerated at an initial dose of 300 mg (one 150 mg injection in each buttock), with subsequent doses being only 150 mg (Kranzler et al., 2004). Side effects, including upper abdominal pain, chest pain, and injection site reactions, were significantly more common in the group taking Naltrel than in those taking placebo. Reasons for discontinuing treatment were similar in the Naltrel and placebo groups, although 13 subjects taking Naltrel (8.2 percent) dropped out of treatment, compared with 6 subjects (3.8 percent) in the placebo group. No serious adverse events were reported in a subsequent 6-week, open-label trial. Sixteen subjects, followed for 6 weeks after a single 300 mg dose of Naltrel intramuscularly, reported 198 side effects. The 17 side effects rated as severe included nausea, flatulence, gastrointestinal pain, fatigue, lethargy, somnolence (two reports), depression, irritability, headache (four reports from three participants), back pain, injection site mass, injection site pain, and an elevated GGT level (Galloway et al., 2005).

In light of one diagnosed and one suspected case of eosinophilic pneumonia in the Vivitrol trials, the manufacturer recommends that physicians consider a diagnosis of eosinophilic pneumonia in any patient receiving injectable naltrexone who develops progressive dyspnea and hypoxemia, as well as the possibility of eosinophilic pneumonia in patients who do not respond to antibiotics.

Conditions excluding treatment with injectable naltrexone. More research is needed to determine whether injectable naltrexone is associated with unexpected adverse or allergic reactions because three subjects in the Vivitrol trials had angioedema or pneumonia, an allergic-type reaction rate of 1:218. The Vivitrol manufacturer states that patients should not be actively drinking at the time Vivitrol is initially administered and that the medication is contraindicated in patients who have previously exhibited hypersensitivity to naltrexone, polylactide-co-glycolide, carboxymethylcellulose, or any other components of the diluent.

Injectable naltrexone is a potent opioid antagonist. Contraindications to the oral form of naltrexone also pertain to the injectable formulations, including the following:

- In patients with acute hepatitis or liver failure and patients with active liver disease, injectable naltrexone must be carefully considered, given naltrexone’s hepatotoxic effects. Use of injectable naltrexone should be discontinued in the event of symptoms or signs of acute hepatitis.
- In patients who are receiving opioid analgesics, patients with current physiologic opioid dependence, and patients in acute opioid withdrawal.
- In individuals who have failed the naloxone challenge test or have a positive urine screen for opioids.

There appears to be at most a fivefold margin between a safe dose of naltrexone and a dose that can cause hepatic injury. Injectable naltrexone at recommended doses does not appear to be a hepatotoxin.

Patients appropriate for injectable naltrexone. In reviewing the clinical evidence on injectable naltrexone, Johnson (2006) concludes that injectable naltrexone could benefit individuals who have failed at outpatient treatment using adjunctive medication, as well as other target populations. Such patients with alcohol dependence include the following:

- Patients who show low compliance with medication resulting from nonspecific factors, such as memory impairment
- Patients who experience marked or prolonged side effects from taking oral naltrexone
- Individuals who experience relatively low therapeutic effects from oral naltrexone, suggesting that a trial with an injectable preparation be done to rule out fluctuating blood levels of naltrexone as a possible cause
- Individuals who expect to be in situations where oral naltrexone might be unavailable or difficult to obtain if lost, such as overseas travelers or military personnel on short assignments
- Individuals detoxified in hospitals and awaiting referral to outpatient treatment so that medication can be available to these patients during the hiatus between detoxification and treatment
- Individuals with co-occurring alcohol and psychiatric disorders, for whom the injectable form would reduce the need for additional pills
- Offenders in forensic facilities or drug courts who could be offered the option of imprisonment or supervised treatment with injectable preparations; clear guidelines and protocols must guide the ethical use of injectable naltrexone in forensic settings.

As reported in the section on oral naltrexone, research demonstrates that people with a family history of alcoholism seem to respond best to this medication. The trials on injectable naltrexone have not explored the connection between such characteristics in men and women and the efficacy of the injectable formulation.

Estimates of efficacy—with a small to medium effect size—seem to be comparable in men taking Vivitrol or Naltrel (Johnson, 2006). However, the potential benefit of injectable naltrexone for women is unclear. The multisite clinical trials showed that injectable naltrexone can reduce heavy drinking in men, but no significant effects were shown in women. Injectable naltrexone seems to effectively reduce relapse and promote abstinence among individuals who are alcohol dependent, but the two published trials did not explore the effect of gender on treatment outcomes.

Injectable vs. Oral Naltrexone

No direct studies have compared the efficacies of oral and injectable naltrexone. The decision on which form of naltrexone to prescribe is likely to be driven by patient characteristics, history, and preferences.

Johnson (2006) delineates five important considerations that need to be resolved if injectable naltrexone is to be used fully in the treatment of alcohol dependence:

1. Training of healthcare providers. Providers need training in proper administration of the injections, which will reduce the likelihood of local site reactions and of resulting noncompliance by patients.
2. Establishment of precedents in psychiatry for initiating an intramuscular rather than an oral medication. Plausible guidelines might include the use of an injectable preparation after a trial of oral naltrexone has failed (presumably because of low compliance) or after a trial of oral naltrexone has shown no untoward side effects or adverse reactions for the patient. To what extent patients in real-world medical clinics will accept voluntary naltrexone injections is unknown.
3. Cost arrangements. Uneven insurance coverage across the United States has hindered the widespread use of oral naltrexone and can be a potential problem for injectable naltrexone. Injectable naltrexone could be limited to patients who have private insurance policies or self-pay.
4. Flexible planning for adequate psychosocial support and monitoring of patient care. Injectable naltrexone preparations have been tested only in conjunction with psychosocial support, which will be particularly important for patients coming in monthly for injections. An adequate standard of patient care will require a flexible approach that can provide such features as initial heightened support to establish a firm therapeutic alliance and a safety net in case of relapse.
5. Attention to emerging knowledge about combining other medications with injectable naltrexone. Preliminary studies suggest that adding other medications may augment the efficacy of naltrexone. If these studies are confirmed, the injectable form of naltrexone will offer important advantages, such as a lowered risk of kinetic interactions, enhanced patient compliance, and a potential for increased pharmacodynamic response against a platform of stable naltrexone levels in the blood.

#### Research needs

The Vivitrol trial, which represents one of the largest samples ever treated with a medication for alcohol dependence, shows that this formulation could improve intervention strategies for alcohol dependence because it can provide a predictable pharmacological foundation for treatment. In addition, it has the clinical benefit of providing a firm basis for combination with other treatments, including psychotherapy, other medications, or both. Additional research will resolve the following issues raised by the multisite trial:

- Better understanding of the effects of injectable naltrexone on women. Treatment effects were highly significant among men taking 380 mg injectable naltrexone but not significant in women. Because only a small number of women were included in the Vivitrol study, they may not be representative of women with alcohol dependence in general. Also, women’s typical heightened response to psychosocial interventions may obscure the medication effects (Garbutt et al., 2005). A recent study found that drinking outcomes with oral naltrexone seemed to be superior for women compared with men (Kiefer, Jahn, & Wiedemann, 2005b). In light of this finding, it has been suggested that the injection delivery method may inhibit its effectiveness for women. The injections may have more frequently been delivered subcutaneously rather than intramuscularly in women, thereby slowing absorption (Johnson, 2006). Recent research on the efficacy of medications injected intramuscularly in the buttocks showed that the higher percentage of body fat in women frequently causes injections into fat rather than into muscle, which can be prevented through use of longer needles. More research is needed.
- More knowledge about treatment duration and special populations. Additional research is needed to determine the optimal duration of treatment with long-acting naltrexone, as well as indicators that treatment can be discontinued. The usefulness of injectable naltrexone for special populations, such as people with a major mental disorder or those in the criminal justice system, is yet to be examined.

### Acamprosate

Acamprosate calcium delayed-release tablets were approved by FDA on July 29, 2004, for treating AUDs in patients who have completed withdrawal from alcohol. Acamprosate, manufactured by Merck KGaA and marketed by Forest Laboratories, Inc., under the brand name Campral^®^, became available to U.S. physicians, patients, and pharmacies on January 11, 2005. The FDA-approved labeling for acamprosate, which is available at the FDA’s Web site (http://www.fda.gov), recommends that acamprosate be used in conjunction with “a comprehensive management program that includes psychosocial support.” FDA approval was based on short- and long-term efficacy and safety data from four double-blind, placebo-controlled randomized trials comparing Campral plus psychotherapy with placebo plus psychotherapy (Forest Laboratories, Inc., 2005). In the three 90- to 360-day trials, which required patients to be abstinent before starting the medication, a greater percentage of those taking acamprosate rather than placebo remained abstinent.

The mechanism of action by which acamprosate maintains abstinence from alcohol is not completely understood, but it differs from the modes of naltrexone or disulfiram. Whereas naltrexone blocks the endogenous opioid reward system, acamprosate is believed to act on neurotransmitter systems in the brain that have been altered by alcohol abuse, returning them from a hyperactive to a normal state. Acamprosate has a structure similar to GABA. It is an inhibitory modulator of NMDA-type excitatory amino acid receptors, perhaps acting indirectly via metabotropic glutamate receptors. It is hypothesized that acamprosate interacts with the glutamate neurotransmitter system thereby regulating the glutamatergic system, which reduces symptoms of withdrawal (reviewed by Litten et al., 2005; Myrick & Anton, 2004). Acamprosate thus may block protracted withdrawal symptoms that could contribute to relapse (Myrick & Anton, 2004). According to De Witte, Littleton, Parot, and Koob (2005), emerging evidence suggests that acamprosate interacts with excitatory glutamergic neurotransmission in general and as an antagonist of the metabotropic glutamate receptor subtype 5 in particular—which provides a unifying, satisfactory hypothesis to explain the diverse neurochemical effects of this medication.

Because of acamprosate’s poor absorption, the recommended dose of Campral is two 333 mg tablets taken three times daily to provide a daily 2 g dose (Forest Laboratories, Inc., 2005; Sofuoglu & Kosten, 2004). Recent U.S. trials have used Campral at an exploratory level of 3 g per day; acamprosate remained safe and well tolerated in a broadly inclusive sample of subjects (Anton et al., 2006; Mason et al., 2006).

#### Research on acamprosate

Over the past 15 years, the safety and efficacy of acamprosate for alcohol dependence have been well established in multiple double-blind, placebo-based trials (Mason, 2005). Overall, in numerous European trials, acamprosate has been consistently associated with greater beneficial effects than placebo on the following measures of alcohol abstinence: greater rates of complete abstinence, longer times to first drink, and/or an increased duration of cumulative abstinence (Mason, 2005). Surprisingly, two recent well-designed, multisite studies of U.S. patients have not shown the level of efficacy for acamprosate that is consistently demonstrated among European patients (Anton et al., 2006; Mason et al., 2006). In addition, a recent study in Australia found that use of acamprosate did not further improve the significant change that outpatients reported in their subjective health status and psychological well-being as a result of receiving CBT alone for their alcohol dependence (Feeney, Connor, Young, Tucker, & McPherson, 2006b).

Acamprosate has been used in conjunction with psychosocial or behavioral counseling to promote abstinence in 26 countries, producing an extensive body of data. By 2000, acamprosate had been studied in 17 randomized, placebo-controlled clinical trials performed in 11 European countries and South Korea and covering approximately 5,000 male and female outpatients. Reviews and several meta-analyses have been done on these trials, which all support the therapeutic effect of acamprosate (Mann, 2004; Mason, 2001; Soyka & Chick, 2003). Outcomes of the clinical trials of acamprosate at a dose of 1,998 mg per day are listed in Exhibit 2 (Mann, 2004).

Exhibit 2 Published Placebo-Controlled Clinical Trials of Acamprosate 1,998 mg/day in Alcohol Dependence^a^

Study | Country | No. of Patients | Duration (mo)^b^ | Outcome Measure | Result^c^
Chick et al., 2000 | Britain | 581 | 6/1.5 | %A | No effect
Lhuintre et al., 1990 | France | 569 | 3/3 | GGT | Decreased
Paille et al., 1995 | France | 538 | 12/6 | %A | Increased
Whitworth et al., 1996 | Austria | 448 | 12/12 | TFD | Increased
Tempesta et al., 2000 | Italy | 330 | 6/3 | %A | Increased
Tempesta et al., 2000 | Italy | 330 | 6/3 | CAD | Increased
Tempesta et al., 2000 | Italy | 330 | 6/3 | TFD | Increased
Barrias et al., 1997 | Portugal | 302 | 12/6 | %A | Increased
Barrias et al., 1997 | Portugal | 302 | 12/6 | CAD | Increased
Gual & Lehert, 2001 | Spain | 288 | 6/none | CAD | Increased
Sass et al., 1996 | Germany | 272 | 11/11 | TFD | Increased
Sass et al., 1996 | Germany | 272 | 11/11 | %A | Increased
Sass et al., 1996 | Germany | 272 | 11/11 | CAD | Increased
Geerlings et al., 1997 | Benelux region^d^ | 262 | 6/6 | CAD | Increased
Geerlings et al., 1997 | Benelux region^d^ | 262 | 6/6 | %A | No effect
Geerlings et al., 1997 | Benelux region^d^ | 262 | 6/6 | TFD | Increased
Poldrugo, 1997 | Italy | 246 | 6/6 | CAD | Increased
Poldrugo, 1997 | Italy | 246 | 6/6 | %A | Increased
Poldrugo, 1997 | Italy | 246 | 6/6 | TFD | Increased
Pelc et al., 1997 | Belgium/France | 188 | 3/none | CAD | Increased
Pelc et al., 1997 | Belgium/France | 188 | 3/none | %A | Increased
Namkoong et al., 2003 | South Korea | 142 | 2/none | TFD | No effect
Namkoong et al., 2003 | South Korea | 142 | 2/none | CAD | No effect
Roussaux et al., 1996 | Belgium | 127 | 6/none | %A | No effect
Besson et al., 1998 | Switzerland | 110 | 12/12 | %A | Increased
Besson et al., 1998 | Switzerland | 110 | 12/12 | CAD | Increased
Pelc et al., 1992 | Belgium | 102 | 6/6 | CAD | Increased
Pelc et al., 1992 | Belgium | 102 | 6/6 | %A | Increased
Pelc et al., 1992 | Belgium | 102 | 6/6 | TFD | Increased
Lhuintre et al., 1985 | France | 70 | 3/none | %A (GGT & MCV) | Increased
Ladewig et al., 1993 | Switzerland | 61 | 6/6 | %A | No effect
Ladewig et al., 1993 | Switzerland | 61 | 6/6 | CAD | Increased

a Studies are ranked by size.

b Duration of treatment/duration of additional followup beyond trial treatment period.

c The results of the studies are identified as “increased” or “decreased” only when the intergroup difference was statistically significant at the level of 0.05.

d Belgium, The Netherlands, and Luxembourg.

CAD = cumulative abstinence duration.

GGT = gamma glutamyltransferase levels.

MCV = mean corpuscular volume.

TFD = time to first drink.

% A = percentage of patients remaining abstinent at study end.

Reprinted with adaptations from CNS Drugs, 18(8), 495, 2004, with permission from Wolters Kluwer Health.

The European acamprosate studies varied in duration from 3 months to more than a year. In 13 of 15 studies, subjects treated with acamprosate had a higher rate of treatment completion, longer time to first drink, and higher abstinence rates compared with subjects treated with placebo (Mason, 2001). In the combined studies, the abstinence rate at the end of treatment in the acamprosate groups was 35 percent versus 21 percent in the placebo groups.

One review of the clinical data concluded that there was some evidence in three studies (those of Chick, Pelc, and Paille and their colleagues) that acamprosate could reduce craving (Mann, 2004). However, other reviewers consider it inaccurate to refer to acamprosate as an anticraving agent; they believe the evidence supports its efficacy only as a medication to prevent relapse, possibly by blocking prolonged withdrawal symptoms (Mason, 2001). Mann (2004) also concluded that, for three studies that failed to show beneficial effects of acamprosate over placebo, the possible reasons were that patient numbers were too small, a 2-month treatment period was used rather than the longer treatment periods used in the other studies, and acamprosate was not started until 25 days after patients had been weaned from alcohol, by which time many subjects were no longer abstinent.

In a recent meta-analysis of 16 studies, the relative benefit of remaining continually abstinent for 6 months after detoxification was quantified as 1.47 for subjects treated with acamprosate compared with subjects receiving placebo (Mann, Lehert, & Morgan, 2004). This meta-analysis also suggested that the relative benefit attributable to acamprosate may increase over time.

#### Acamprosate use in primary care

Current data suggest that acamprosate may be equally useful in primary care and in specialized substance abuse treatment settings (Mann, 2004). A number of Phase IV studies of acamprosate have been made under naturalistic practice conditions that basically confirm the abstinence rates found in the placebo-controlled trials (Pelc et al., 2002; Soyka, Preuss, & Schuetz, 2002). A pragmatic trial in France compared results when 149 general practitioners, who were accustomed to managing patients in their practice, added acamprosate to standard treatment. A very high percentage of patients successfully completed the 1-year followup period (348 of 422 patients or 82.5 percent). The duration of abstinence compared well with the clinical trials: 0.67 for standard care and 0.81 for acamprosate. In clinical practice, this means that patients taking acamprosate could be expected to remain abstinent for 23 percent longer on average than patients on standard care and to experience about 2 months more abstinence during a 1-year treatment period (Kiritze-Topor et al., 2004). However, the principal finding was that adjunctive therapy with acamprosate was associated with a significantly better outcome in patients’ quality of life, based on social, medical, and economic measures.

The first U.S. study to evaluate the clinical efficacy of acamprosate compared the safety and effects of the standard 2 g dose, an exploratory 3 g dose, or placebo in a double-blind, 6‐month trial conducted among 601 volunteers in 21 outpatient clinics across the United States (Mason et al., 2006). All patients received the drug or placebo plus eight concomitant sessions of brief, manual-guided counseling (http://www.alcoholfree.info). The main outcome measure was the percentage of alcohol-free days over the 6-month period. Surprisingly, the percentage of abstinent days did not differ significantly across groups in the a priori analysis (54.3 percent for placebo, 56.1 percent for 2 g acamprosate, and 60.7 percent for 3 g). However, the researchers used standardized assessments to characterize the subjects at baseline according to such potential covariates as baseline goal of total abstinence, alcoholism severity, stage of readiness to change, treatment exposure, and such psychological precedents as psychiatric hospitalizations or suicide attempts. Analysis of these covariates showed that acamprosate was associated with a significantly higher percentage of abstinent days than placebo in the subgroup of patients who had a baseline goal of abstinence (58.1 percent for placebo, 70.0 percent for 2 g acamprosate, and 72.5 percent for 3 g). Researchers concluded that acamprosate has an appreciable treatment effect among patients who have abstinence as a treatment goal.

In the COMBINE study, all groups showed substantial reduction in drinking. This multisite, U.S. study used a 3 g daily dose of acamprosate. However, the study found no evidence of efficacy for acamprosate and no evidence of incremental efficacy for combinations of naltrexone, acamprosate, and combined behavioral intervention (Anton et al., 2006). The lack of acamprosate efficacy was unexpected, given the positive results of many previous trials (Anton et al., 2006). The substantial improvement shown by all COMBINE groups, possibly in part as a result of the attention within the study itself (the “Hawthorne effect”), may have lessened the study’s power to show an impact from the acamprosate.

Adverse events. The international and U.S. clinical trials demonstrated a favorable safety and tolerability profile (Garbutt, West, Carey, Lohr, & Crews, 1999; Mason, 2001). Side effects are generally mild, with the most frequent side effect being short-term diarrhea that is dose related and transient (Boothby & Doering, 2005). Very few patients drop out of treatment because of adverse effects. There is no risk of alcohol interactions with acamprosate, and there is no abuse potential (Mason, 2001). Participants in the first U.S. multisite trial experienced no deaths or serious drug-related adverse events (Mason et al., 2006). The COMBINE trial, using acamprosate at a 3 g dosage, found no problems with either adverse events or medication adherence (Anton et al., 2006).

Conditions excluding treatment with acamprosate. Acamprosate is contraindicated in patients with severe renal impairment and requires a dose reduction for patients with moderate renal impairment (Forest Laboratories, Inc., 2005). However, this medication may be particularly useful in patients with hepatic impairment and/or liver disease (Scott, Figgitt, Keam, & Waugh, 2005).

Patients appropriate for acamprosate.Mason and colleagues (2006) suggest that their U.S. multisite trial was “perhaps the most definitive evidence to date that acamprosate is not an effective treatment for alcohol dependence in non-motivated and non-abstinent populations.”

Acamprosate is a proven effective intervention for treatment of alcohol dependence. However, acamprosate prevents lapses or relapses only in a minority of patients. Two important questions, therefore, are (1) whether acamprosate is more effective when combined with particular types of psychosocial treatment and (2) whether specific subgroups of patients respond particularly well to acamprosate.

Three Phase IV studies failed to find any significant differences in outcome among various psychosocial treatment groups, which included individual therapy, group therapy, brief therapy, and CBT. A pooled analysis of seven trials, covering 1,485 patients, was unable to identify a positive predictor of efficacy with acamprosate treatment, suggesting that acamprosate can be considered a potentially effective pharmacotherapy for all patients (Verheul, Lehert, Geerlings, Koeter, & van den Brink, 2005). The variables looked at, none of which predicted efficacy with acamprosate, included family history of alcoholism, late age of onset, female gender, high physiological dependence, serious anxiety symptomatology, and severe craving at baseline.

Soyka and Chick (2003) recommend that patients be given an initial prescription trial of acamprosate and, if they manage to abstain, they should continue receiving the drug for 1 year. Both the European and U.S. studies suggest that treatment needs to be initiated as soon as possible after the period of alcohol withdrawal, once the patient has achieved abstinence (Soyka & Chick, 2003). Acamprosate should not be stopped if the patient lapses because this medication appears to have a small effect in reducing drinking following a relapse (Chick, Lehert, & Landron, 2003).

#### Research needs

More research is needed to understand the different outcomes of the international versus the U.S. trials on efficacy of acamprosate. Understanding why the research results are discrepant can have important clinical implications. A number of possible reasons have been postulated for the failure of U.S. studies to show the efficacy for acamprosate shown in nearly all international studies:

- Differences in U.S. and European drinking patterns
- Length of clinical trials (European trials are generally longer than U.S. trials)
- More standardized, manual-based psychosocial treatments in U.S. trials, which may result in more consistently improved patient outcomes that reduce the perceived effect of the added medication (Mason et al., 2006)
- Differences in length of pretreatment abstinence preceding the medication (COMBINE required only 4 days of abstinence, achieved primarily on an outpatient basis, whereas most positive studies of acamprosate have a longer pretreatment abstinence period established during inpatient treatment) (Anton et al., 2006).

## Combined Medication Therapy

Currently, much scientific and clinical interest focuses on combining therapeutic agents to treat alcohol dependence. This interest is predicated on the hypothesis that multiple neurochemical pathways may be deranged as either “state” or “trait” effects of the drinking behavior, so combining effective medications that work at different neurotransmitters may produce a synergistic or at least added response (Johnson & Ait-Daoud, 2000). Knowledge is growing about how the various neurotransmitters interact in the brains of people who are alcohol dependent, as well as how this interaction may vary in different stages of the addiction. In the meantime, practical trials are being conducted that combine medications that have some demonstrated effectiveness in clinical settings, such as naltrexone and acamprosate. These trials will help determine the treatment response to combination therapies, as well as delineate the subgroups of patients most positively affected by the various combinations.

The treatment field has considerable interest in the use of therapeutic medications alone or in combination to treat patients who have co-occurring alcohol and mental disorders. The rate of substance use is higher among patients who have psychotic-spectrum mental illnesses, such as schizophrenia, schizoaffective disorder, and bipolar disorder. In a recent review of the small but growing body of literature on the use of disulfiram and naltrexone for alcoholism in patients with co-occurring mental disease, Petrakis, Nich, and Ralevski (2006a) concluded that the literature supports the use of these medications for patients with co-occurring psychotic-spectrum disorders. Recent research on pharmacological treatment for such patients includes the following:

- A 12-week randomized clinical trial of disulfiram and naltrexone each alone and in combination was conducted on individuals with Axis I disorders and alcohol dependence who were receiving intensive psychosocial treatment. Compared with controls on placebo, patients with psychotic-spectrum disorder had better alcohol outcomes on an active medication, but no clear advantage was seen for disulfiram, naltrexone, or the combination. Retention rates and medication compliance were high, exceeding 80 percent (Petrakis et al., 2006a).
- Both disulfiram and naltrexone were effective and safe in a subgroup of 93 veteran outpatients in this randomized trial who had posttraumatic stress disorder (PTSD) and co-occurring alcohol dependence. Patients had better alcohol outcomes with naltrexone, disulfiram, or the combination than they did on placebo; their overall PTSD psychiatric symptoms also improved (Petrakis et al., 2006b).
- A 16-week, open-label pilot study of naltrexone with 34 outpatients who had bipolar disorder and alcohol dependence found that the medication was well tolerated. Patients showed significant improvement on rating scales for depression and mania, and days of alcohol use and craving decreased significantly (Brown, Beard, Dobbs, & Rush, 2006).

### Disulfiram Combined With Acamprosate

Concomitant administration of disulfiram with acamprosate may improve the effectiveness of acamprosate. Besson and colleagues (1998) conducted a double-blind study of 118 patients who were randomly given acamprosate or placebo, with both groups stratified for voluntary, concomitant use of disulfiram. Treatment lasted for 360 days, with a 360-day followup. The subgroup that received both medications had better outcomes with regard to duration of its cumulative abstinence than did the subgroups on one or no medication. No adverse interaction occurred in patients taking concomitant disulfiram and acamprosate, with diarrhea being the only significant treatment-induced effect.

### Acamprosate Combined With Naltrexone

Since 1995, an extensive body of clinical trial data indicates that both acamprosate and naltrexone are effective in the treatment of alcohol dependence. Clinical trials with acamprosate demonstrate that this drug significantly increases the proportion of patients who remain abstinent after acute detoxification (Mann et al., 2004; Mason, 2001). For naltrexone, the most reproducible finding is that it reduces relapse into heavy drinking (Kranzler & Van Kirk, 2001; Streeton & Whelan, 2001). Some studies show that naltrexone reduces craving and the desire to drink in social drinkers and in people with alcohol dependence who are both abstinent and nonabstinent (Kiefer & Wiedemann, 2004).

However, each drug has been shown to be effective in only 20 to 50 percent of unselected patients with alcoholism (Kreek et al., 2002). Because the two drugs have different pharmacological mechanisms of action and appear to act on different behavioral aspects of alcohol dependence, combining these drugs might provide greater benefit than either provide alone.

Kiefer and Wiedemann (2004) reviewed three preclinical and four clinical studies published since 2000 on the pharmacologic aspects of combined treatment. Their meta-analysis concluded that the combination of acamprosate with naltrexone seems to be both safe and effective, with no negative effects on safety or cognitive function (Kiefer & Wiedemann, 2004). The available data show no severe adverse events during the combined treatment, with diarrhea and nausea being the most significant side effects. The clinical data showed that combined treatment was superior to both placebo and therapy with acamprosate alone. The synergistic effect of combined treatment remained after 12 weeks of drug-free followup (Kiefer & Wiedemann, 2004). A recent 12-week, single-site study in Australia found that the combination of acamprosate and naltrexone, with CBT, was superior to either medication alone for alcohol abstinence (Feeney, Connor, Young, Tucker, & McPherson, 2006a). Naltrexone alone with CBT was slightly less effective on all measures than the combined medication. Studies suggest the following explanations for a potentiated effect from the combined drugs:

- The administration of acamprosate with naltrexone unexpectedly—and significantly—increased the rate and extent of absorption of acamprosate by about 33 percent (Johnson et al., 2003b; Mason et al., 2002). This suggests that combination treatment may make acamprosate more available systemically with no decrease in tolerability, which may provide clinical advantages.
- Some patient subgroups may respond preferentially to the anticraving effects of either drug—either being “reward cravers” (naltrexone) or “relief cravers” (acamprosate) or because of other as yet undetermined factors (Kiefer & Wiedemann, 2004). Pharmacological anticraving treatment may also be more effective with patients who have early-onset alcohol dependence (Johnson, Ait-Daoud, & Prihoda, 2000). Larger prospective studies need to evaluate whether any factors can predict a positive response to anticraving treatment.
- The combination of naltrexone and acamprosate may produce a more incisive anticraving effect in patients than either drug alone. Such a synergy could result from two drugs interfering with two distinct biological aspects of the craving process—reward and relief craving. If this is true, then it would be unlikely that distinct groups would respond preferentially to either drug (Keifer & Wiedemann, 2004).

Although more testing is needed, the results to date suggest that some patients could benefit from combined acamprosate–naltrexone therapy (Kiefer & Wiedemann, 2004). The combined treatment could benefit particularly those patients who have had an inadequate response to either naltrexone or acamprosate alone (Kiefer & Wiedemann, 2004).

### The COMBINE Clinical Trial

So far, only a limited number of controlled clinical trials have been conducted on combination treatments. Both researchers and practitioners have been eagerly awaiting results from the COMBINE study, NIAAA’s sophisticated, 11-site combination therapy trial with almost 1,400 subjects in the context of primary care and other nonspecialty treatment settings. In addition to comparing the efficacy of naltrexone and acamprosate separately and together for 16 weeks, the study also looked at these pharmacotherapies in combination with different intensities of behavioral interventions. (Note: The behavioral interventions integrate successful elements of those evaluated in NIAAA’s Project MATCH.) The COMBINE study had two pilot studies, which showed the safety and feasibility of the approach (COMBINE Study Research Group, 2003).

This randomized clinical trial was conducted from January 2001 to January 2004 among volunteers who were recently alcohol abstinent (median age 44 years) and who had a Diagnostic and Statistical Manual of Mental Disorders (American Psychiatric Association, 1994) diagnosis of primary alcohol dependence. Eight groups of patients received medical management combined with 16 weeks of naltrexone (100 mg/day), acamprosate (3 g/day), both medications, and/or placebos—both with and without a combined behavioral intervention (CBI). Patients were evaluated at 16 weeks and for up to 1 year after treatment, looking at the percentage of days they were abstinent from alcohol and the time elapsed to their first heavy drinking day. Results were as follows:

- All groups showed substantial reductions in drinking.
- A significant interaction was found in those receiving naltrexone + a behavioral intervention. Patients receiving (1) naltrexone + medical management, (2) CBI + medical management + placebos, or (3) naltrexone + CBI + medical management had a higher percentage of days abstinent (80.6, 79.2, and 77.1, respectively) than the 75.1 percent among those who received placebos and medical management only.
- Naltrexone reduced the risk of a heavy drinking day, which was most evident in those receiving medical management but not CBI.
- Acamprosate, unexpectedly, showed no significant effect on drinking versus placebo, either by itself or with any combination of naltrexone, CBI, or both. This result was unexpected, because the study hypothesis and an earlier COMBINE single-site study had supported the combined use of acamprosate and naltrexone (Kiefer & Wiedemann, 2004). However, because all groups in this study, including the control groups, showed significant reductions in drinking, the power necessary to detect a statistically significant difference between groups may have been lost. As Johnson (2006) points out, pharmacotherapy trials increasingly demonstrate that the greatest treatment effect comes from being enrolled in a study irrespective of the treatment condition; this can make any statistically significant difference between the active medication and placebo groups seem relatively small clinically.

A major finding of the COMBINE study was that patients who received medical management with naltrexone or with behavioral intervention or the combination of both fared better on drinking outcomes than those on acamprosate. Other significant findings included the following:

- Medical management in primary care settings can be an effective means of treating alcohol-dependent populations. Most COMBINE groups received a nine-session medical management intervention that focused on enhancing medication adherence and abstinence, using a model that could be adapted by primary care settings. In the context of medical management, naltrexone yielded outcomes similar to those from behavioral treatment provided by substance abuse treatment specialists. Unexpectedly, the patients who received medical management and placebo showed a positive effect over and above that seen in patients who received only specialist-delivered behavioral therapy.
- At 1 year after treatment, the COMBINE study found that the differential effects of treatment still persisted, but these effects were only marginally significant. These results suggest that a number of individuals require either prolonged or intermittent care. This tends to validate previous research suggesting that useful approaches for those who do well during initial treatment would be (1) continued naltrexone and medical monitoring, (2) the continuation of behavioral intervention, or (3) both continued naltrexone–medical monitoring and behavioral intervention (Anton et al., 2006).

## Research on Promising Drugs

People who develop chronic alcoholism, either because of being genetically at risk or because of sustained, persistent heavy use, ultimately develop brain changes (Anton, 2002). Neuroadaptive changes, or sensitized changes, mean that the brains of people with alcohol dependence are definitely different, both from the brains that they had before they started drinking heavily and from the brains of social drinkers. Through medication, physicians can affect alcoholism in three major areas: (1) reward or reinforcement, (2) protracted withdrawal, and (3) disorder or impulse control (Anton, 2002).

Current research on drugs could potentially be effective in each of these areas. For example, nalmefene and ondansetron are drugs being tested that may work on the patient’s reward system. The selective serotonin reuptake inhibitors (SSRIs) and buspirone work on serotonergic systems, trying to stabilize affective or impulsive conditions that may work, along with the reward mechanisms, to increase a person’s risk of relapse to persistent alcohol use (Anton, 2002). A second rationale for the use of serotonergic drugs in alcohol pharmacotherapy is that studies have clearly shown that serotonin modulates the mesolimbic dopamine transmission. It has been suggested that serotonin-dependent activation of dopaminergic neurons in the ventral tegmental area contributes to the reinforcing effects of alcohol consumption (Tambour & Quertemont, 2007).

Because of the increased understanding of the neurobiology of alcoholism, researchers can study combinations of agents that act on different neurotransmitter systems and can potentially enhance the effect of either medication alone. There is particular interest in potential combinations of naltrexone with other drugs for specific conditions. Some preliminary reports suggest that combining naltrexone with ondansetron may be of some use (Ait-Daoud, Johnson, Prihoda, & Hargita, 2001). Some pharmacologic agents now being studied include the following:

- Opiate receptor antagonists. Nalmefene, which may have a profile similar to naltrexone, shows promising activity in single-site pilot studies (Mann, 2004), but a multisite study found no evidence of superior efficacy outcomes with nalmefene treatment over placebo (Anton et al., 2004). A 2005 meta-analysis of the available research concluded that the evidence on nalmefene was insufficient at that time to warrant use (Srisurapanont & Jarusuraisin, 2005). However, a Finnish multisite, randomized double-blind study recently found that targeted nalmefene was more effective than placebo at reducing heavy drinking among 403 subjects in alcohol treatment centers and private general practices (Karhuvaara et al., 2007). This study is described above in Updated Findings From the Literature, October 2007.
- Serotonergic agents. SSRIs have not proved to have much effect on drinking behavior when used alone, but they might be effective in combination with other drugs. Some studies suggest that SSRIs may be useful in reducing alcohol use among people with Type A alcoholism, as classified by Babor and colleagues (Myrick & Anton, 2004) and that SSRIs may be just as effective for treating depression in people who are alcohol dependent as in those without alcohol problems (Anton, 2002). The serotonin type-3 antagonist ondansetron has shown promise in subjects with early-onset alcohol dependence but needs more extensive study (Anton & Swift, 2003). Some preliminary reports also suggest that combining naltrexone with SSRIs may be of some use.
- Anticonvulsant agents. Double-blind, placebo-controlled trials of carbamazepine, divalproex, and topiramate have shown positive effects on several measures of drinking behavior and craving among patients. In 2007, the anticonvulsant drug topiramate was reported to be a safe, consistent, and efficacious treatment for alcohol dependence in a large, multisite study (Johnson et al., 2007) done to replicate and extend an earlier small, double-blind, placebo-controlled trial. The positive findings of this large, multisite trial of topiramate are described above in Updated Findings from the Literature, October 2007.

## Extent of Pharmacotherapy Use by Medical Care Providers

Only a small percentage of practitioners use the available pharmacotherapies for treating addiction. This pattern of underuse is found in every professional group studied, including general practitioners, family physicians, VA physicians, and addiction psychiatrists (Petrakis, Leslie, & Rosenheck, 2003; Thomas et al., 2003). For example, one study found that addiction specialists were prescribing naltrexone to only 3 to 13 percent of their patients (Mark, Kranzler, & Song, 2003b). If pharmacotherapies are to be used at an optimum level, then medical administrators and specialty treatment programs will need to address the reasons for physicians’ reluctance to use these medications. Reasons for nonuse tend to be the same across studies and include the following:

- Lack of awareness about the medication (pharmaceutical companies have not provided information about drugs for addiction—to professionals or consumers—as they have for other medications)
- Lack of knowledge about efficacy of the drug in practice, as well as a perceived lack of evidence that the drug would be effective
- The time required for patient management
- Lack of reimbursement and inability of patients to pay for the drug (Mark et al., 2003a).

When physicians have more information about a drug, they prescribe it more (Mark et al., 2003b). A drug such as naltrexone is used more often when the treatment organization in which physicians work promotes its use (Thomas et al., 2003). In addition, several studies indicate that patients have better outcomes when the physician believes that a medication will be effective. Several studies, particularly those pertaining to methadone or buprenorphine, reported that training of physicians resulted in much more positive attitudes about treating patients who are drug dependent and about the value of pharmacotherapy (McCarty, Rieckmann, Green, Gallon, & Knudsen, 2004).

Although substance use disorders constitute one of the most significant public health issues in the United States, there is evidence that physicians frequently do not appropriately screen, diagnose, provide treatment interventions, or make referrals to specialists for patients with these disorders (AMA Council on Medical Education, 2007). Physicians receive little or no training on treating addictions during medical school. In 2005–2006, just 46 percent of U.S. medical schools offered both required and elective course hours on the topic of substance abuse, and the mean number of course hours required was less than 16 (AMA Council on Medical Education, 2007). It is becoming increasingly important that physicians gain more professional knowledge in this area.

## References

Ait-Daoud N, Johnson BA, Prihoda TJ, Hargita ID. Combining ondansetron and naltrexone reduces craving among biologically predisposed alcoholics: Preliminary clinical evidence. Psychopharmacology. 2001;154:23-27. [pmid: 11292002].
Ait-Daoud N, Malcolm RJ, Johnson BA. An overview of medications for the treatment of alcohol withdrawal and alcohol dependence with an emphasis on the use of older and newer anticonvulsants. Addictive Behaviors. 2006;31(9):1628-1649. [pmid: 16472931].
AMA Council on Medical Education. 2007. Report 11: The status of education in substance use disorders in America’s medical schools and residency programs. Retrieved October 29, 2007, from http://www.ama-assn.org/ama1/pub/upload/mm/377/a-07cmerpt11.pdf.
American Psychiatric Association. 1994. Diagnostic and statistical manual of mental disorders. 4th ed., text revision. Washington, DC. Author.
Anton R. 2002. December. Opioid antagonists alone and in combination with other medications. Symposium III: Pharmacotherapy of Alcoholism. Presentation at the American Academy of Addiction Psychiatry 13th Annual Meeting and Symposium. Las Vegas, NV.
Anton RF. Pharmacologic approaches to the management of alcoholism. Journal of Clinical Psychiatry. 2001;62(Suppl 20):11-17. [pmid: 11584870].
Anton RF, Moak DH, Latham P, Waid LR, Myrick H, Voronin K, et al. Naltrexone combined with either cognitive behavioral or motivational enhancement therapy for alcohol dependence. Journal of Clinical Psychopharmacology. 2005;25(4):349-357. [pmid: 16012278].
Anton RF, Moak DH, Waid LR, Latham PK, Malcolm RJ, Dias JK. Naltrexone and cognitive behavioral therapy for the treatment of outpatient alcoholics: Results of a placebo-controlled trial. American Journal of Psychiatry. 1999;156(11):1758-1764. [pmid: 10553740].
Anton RF, O’Malley SS, Ciraulo DA, Cisler RA, Couper D, Donovan DM, et al. COMBINE Study Research Group. Combined pharmacotherapies and behavioral interventions for alcohol dependence: The COMBINE study, A randomized controlled trial. JAMA. 2006;295(17):2003-2017. [pmid: 16670409].
Anton RF, Pettinati H, Zweben A, Kranzler HR, Johnson B, Bohn MJ, et al. A multisite dose ranging study of nalmefene in the treatment of alcohol dependence. Journal of Clinical Psychopharmacology. 2004;24(4):421-428. [pmid: 15232334].
Anton RF, Swift RM. Current pharmacotherapies of alcoholism: A U.S. perspective. American Journal on Addictions. 2003;12(Suppl 1):S53-S68. [pmid: 14972780].
Assanangkornchai S, Srisurapanont M. The treatment of alcohol dependence. Current Opinion in Psychiatry. 2007;20:222-227. [pmid: 17415073].
Babor TF, Hofmann M, DelBoca FK, Hesselbrock V, Meyer RE, Dolinsky ZS, et al. Types of alcoholics, I. Evidence for an empirically derived typology based on indicators of vulnerability and severity. Archives of General Psychiatry. 1992;49(8):599-608. [pmid: 1637250].
Balldin J, Berglund M, Borg S, Månsson M, Bendtsen P, Franck J, et al. A 6­month controlled naltrexone study: Combined effect with cognitive behavioral therapy in outpatient treatment of alcohol dependence. Alcoholism Clinical Experimental Research. 2003;27(7):1142-1149.
Baros AM, Latham PK, Moak DH, Voronin K, Anton RF. What role does measuring medication compliance play in evaluating the efficacy of naltrexone?. Alcoholism: Clinical and Experimental Research. 2007;31(4):596-603.
Barrias JA, Chabac S, Ferreira L, Fonte A, Potgieter AS, Teixeira de Sousa E. Acamprosate: Multicenter Portuguese efficacy and tolerance evaluation study. Psiquiatria Clinica. 1997;18:149-160.
Besson J, Aeby F, Kasas A, Lehert P, Potgieter A. Combined efficacy of acamprosate and disulfiram in the treatment of alcoholism: A controlled study. Alcoholism: Clinical and Experimental Research. 1998;22(3):573-579.
Bevilacqua JA, Diaz M, Diaz V, Silva C, Fruns M. Disulfiram neuropathy. Report of 3 cases. La Revista Médica de Chile. 2002;130(9):1037-1042.
Boothby LA, Doering PL. Acamprosate for the treatment of alcohol dependence. Clinical Therapeutics. 2005;27(6):695-714. [pmid: 16117977].
Bouza C, Magro A, Muñoz A, Amate JM. Efficacy and safety of naltrexone and acamprosate in the treatment of alcohol dependence: A systematic review. Addiction. 2004;99(7):811-828. [pmid: 15200577].
Brewer C, Hardt F. Preventing disulfiram hepatitis in alcohol abusers: Inappropriate guidelines and the significance of nickel allergy. Addiction Biology. 1999;4(3):303-308. [pmid: 20575796].
Brewer C, Meyers RJ, Johnsen J. Does disulfiram help to prevent relapse in alcohol abuse?. CNS Drugs. 2000;14(5):329-341.
Brown ES, Beard L, Dobbs L, Rush AJ. Naltrexone in patients with bipolar disorder and alcohol dependence. Depression and Anxiety. 2006;23(8):492-495. [pmid: 16841344].
Carroll KM, Nich C, Ball SA, McCance E, Frankforter TL, Rounsaville BJ. One-year follow-up of disulfiram and psychotherapy for cocaine–alcohol users: Sustained effects of treatment. Addiction. 2000;95(9):1335-1349. [pmid: 11048353].
Carroll KM, Rounsaville BJ. A perfect platform: Combining contingency management with medications for drug abuse. American Journal of Drug and Alcohol Abuse. 2007;33(3):343-365. [pmid: 17613963].
Center for Substance Abuse Treatment. 1998. Naltrexone and alcoholism treatment. Treatment Improvement Protocol Series 28. HHS Publication No. (SMA) 98-3206. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Chick J. Safety issues concerning the use of disulfiram in treating alcohol dependence. Drug Safety. 1999;20(5):427-435. [pmid: 10348093].
Chick J, Anton R, Checinski K, Croop R, Drummond DC, Farmer R, et al. A multicentre, randomised, double-blind, placebo-controlled trial of naltrexone in the treatment of alcohol dependence or abuse. Alcohol & Alcoholism. 2000;35(6):587-593. [pmid: 11093966].
Chick J, Lehert P, Landron F. Plinius Maior Society. Does acamprosate improve reduction of drinking as well as aiding abstinence?. Journal of Psychopharmacology. 2003;17(4):397-402. [pmid: 14870951].
COMBINE Study Research Group. Testing combined pharmacotherapies and behavioral interventions in alcohol dependence: Rationale and methods. Alcohol: Clinical and Experimental Research. 2003;27(7):1107-1122.
Comer SD, Collins ED, Kleber HD, Nuwayser ES, Kerrigan JH, Fischman MW. Depot naltrexone: Long-lasting antagonism of the effects of heroin in humans. Psychopharmacology. 2002;159(4):351-360. [pmid: 11823887].
Croop RS, Faulkner EB, Labriola DF. the Naltrexone Usage Study Group. The safety profile of naltrexone in the treatment of alcoholism: Results from a multicenter usage study. Archives of General Psychiatry. 1997;54:1130-1135. [pmid: 9400350].
Davidson D, Gulliver SB, Longabaugh R, Wirtz PW, Swift R. Building better cognitive-behavioral therapy: Is broad-spectrum treatment more effective than motivational-enhancement therapy for alcohol-dependent patients treated with naltrexone?. Journal of Studies on Alcohol and Drugs. 2007;68(2):238-247. [pmid: 17286342].
Davidson D, Palfai T, Bird C, Swift R. Effects of naltrexone on alcohol self-administration in heavy drinkers. Alcoholism: Clinical and Experimental Research. 1999;23:195-203.
De Witte P, Littleton J, Parot P, Koob G. Neuroprotective and abstinence-promoting effects of acamprosate: Elucidating the mechanism of action. CNS Drugs. 2005;19(6):517-537. [pmid: 15963001].
Ducharme LJ, Knudsen HK, Roman PM. Trends in the adoption of medications for alcohol dependence. Journal of Clinical Psychopharmacology. 2006;26(Suppl 1):S13-S19. [pmid: 17114950].
Dunbar JL, Turncliff RZ, Dong Q, Silverman BL, Ehrich EW, Lasseter KC. Single- and multiple-dose pharmacokinetics of long-acting injectable naltrexone. Alcoholism: Clinical and Experimental Research. 2006;30(3):480-490.
Evans SM, Levin FR, Brooks DJ, Garawi F. A pilot double-blind treatment trial of memantine for alcohol dependence. Alcoholism: Clinical and Experimental Research. 2007;31(5):775-782.
Feeney GF, Connor JP, Young RM, Tucker J, McPherson A. Combined acamprosate and naltrexone with cognitive behavioural therapy is superior to either medication alone for alcohol abstinence: A single centre’s experience with pharmacotherapy. Alcohol & Alcoholism. 2006a;41(3):321-327. [pmid: 16467406].
Feeney GF, Connor JP, Young RM, Tucker J, McPherson A. Is acamprosate use in alcohol dependence treatment reflected in improved subjective health status outcomes beyond cognitive behavioural therapy alone?. Journal of Addictive Diseases. 2006b;25(4):49-58. [pmid: 17088225].
Fernández Miranda JJ, Marina González PA, Montes Pérez M, Diaz González T, Gutiérrez Cienfuegos E, Antuña Diaz MJ, et al. Topiramate as add-on therapy in non-respondent alcohol dependent patients: A 12 month follow-up study. Actas Españolas de Psiquiatría. 2007;35(4):236-242. [pmid: 17592785].
Forest Laboratories, Inc. 2005. January 11. Press release: First new treatment for alcoholism in ten years, now available. New York. Author. Retrieved June 16, 2005, from http://www.campral.com.
Fuller RK, Branchey L, Brightwell DR, Derman RM, Emrick CD, Iber FL, et al. Disulfiram treatment of alcoholism: A Veterans Administration Cooperative Study. Journal of the American Medical Association. 1986;256:1449-1455. [pmid: 3528541].
Fuller RK, Gordis E. For debate: Does disulfiram have a role in alcoholism treatment today?. Addiction. 2004;99:21-24. [pmid: 14678055].
Galloway GP, Koch M, Cello R, Smith DE. Pharmacokinetics, safety, and tolerability of a depot formulation of naltrexone in alcoholics: An open-label trial. BMC Psychiatry. 2005;5:18-28. Retrieved May 27, 2005, from http//:www.biomedcentral.com/1471-244X-5-18.
Garbutt JC, Kranzler HR, O’Malley SS, Gastfriend DR, Pettinati HM, Silverman BL, et al. for the Vivitrex Study Group. Efficacy and tolerability of long-acting injectable naltrexone for alcohol dependence: A randomized controlled trial. JAMA. 2005;293(13):1617-1625. [pmid: 15811981].
Garbutt JC, West SL, Carey TS, Lohr KN, Crews FT. Pharmacological treatment of alcohol dependence: A review of the evidence. JAMA. 1999;281:1318-1325. [pmid: 10208148].
Gastpar M, Bonnet U, Böning J, Mann K, Schmidt LG, Soyka M, et al. Lack of efficacy of naltrexone in the prevention of alcohol relapse: Results from a German multicenter study. Journal of Clinical Psychopharmacology. 2002;22(6):592-598. [pmid: 12454559].
Geerlings PJ, Ansoms C, Van Der Brink W. Acamprosate and prevention of relapse in alcoholics. European Addiction Research. 1997;3:129-137.
Gelernter J, Gueorguieva R, Kranzler HR, Zhang H, Cramer J, Rosenheck R, et al. the VA Cooperative Study #425 Study Group. Opioid Receptor Gene (OPRM1, OPRK1, and OPRD1) variants and response to naltrexone treatment for alcohol dependence: Results from the VA Cooperative Study. Alcoholism: Clinical & Experimental Research. 2007;31(4):555-563.
Gual A, Lehert P. Acamprosate during and after acute alcohol withdrawal: A double-blind placebo-controlled study in Spain. Alcohol & Alcoholism. 2001;36(5):413-418. [pmid: 11524307].
Guardia J, Caso C, Arias F, Gual A, Sanahuja J, Ramírez M, et al. A double-blind, placebo-controlled study of naltrexone in the treatment of alcohol-dependence disorder: Results from a multicenter clinical trial. Alcoholism: Clinical and Experimental Research. 2002;26(9):1381-1387.
Gueorguieva R, Wu R, Pittman B, Cramer J, Rosenheck RA, O’Malley SS, et al. New insights into the efficacy of naltrexone based on trajectory-based reanalyses of two negative clinical trials. Biological Psychiatry. 2007;61(11):1290-1295. [pmid: 17224132].
Guzik P, Bankes L, Brown TM. Acamprosate and primitive reflexes. Annals of Pharmacotherapy. 2007;41(4):715-718. [pmid: 17389668].
Heinälä P, Alho H, Kiianmaa K, Lönnqvist J, Kuoppasalmi K, Sinclair JD. Targeted use of naltrexone without prior detoxification in the treatment of alcohol dependence: A factorial double-blind, placebo-controlled trial. Journal of Clinical Psychopharmacology. 2001;21(3):287-292. [pmid: 11386491].
Hersh D, Van Kirk JR, Kranzler HR. Naltrexone treatment of comorbid alcohol and cocaine use disorders. Psychopharmacology (Berl). 1998;139(1–2):44-52. [pmid: 9768541].
Johnson BA. A synopsis of the pharmacological rationale, properties, and therapeutic effects of depot preparations of naltrexone for treating alcohol dependence. Expert Opinion on Pharmacotherapy. 2006;7(8):1065-1073. [pmid: 16722816].
Johnson BA, Ait-Daoud N. Neuropharmacological treatments for alcoholism: Scientific basis and clinical findings. Psychopharmacology. 2000;149:327-344. [pmid: 10867960].
Johnson BA, Ait-Daoud N, Aubin HJ, van den Brink W, Guzzetta R, Loewy J, et al. A pilot evaluation of the safety and tolerability of repeat dose administration of long-acting injectable naltrexone (Vivitrex) in patients with alcohol dependence. Alcoholism: Clinical and Experimental Research. 2004;28(9):1356-1361.
Johnson BA, Ait-Daoud N, Bowden CL, DiClemente CC, Roache JD, Lawson K, et al. Oral topiramate for treatment of alcohol dependence: A randomized controlled trial. Lancet. 2003a;361(9370):1677-1685. [pmid: 12767733].
Johnson BA, Ait-Daoud N, Prihoda TJ. Combing ondansetron and naltrexone effectively treats biological predisposed alcoholics: From hypothesis to preliminary clinical evidence. Alcoholism: Clinical Experimental Research. 2000;24(5):737-742.
Johnson BA, Mann K, Willenbring ML, Litten RZ, Swift RM, Lesch OM, et al. Challenges and opportunities for medications development in alcoholism: An international perspective on collaborations between academia and industry. Alcoholism: Clinical and Experimental Research. 2005;29(8):1528-1540.
Johnson BA, O’Malley SS, Ciraulo DA, Roache JD, Chambers RA, Sarid-Segal O, et al. Dose-ranging kinetics and behavioral pharmacology of naltrexone and acamprosate, both alone and combined, in alcohol-dependent subjects. Journal of Clinical Psychopharmacology. 2003b;23(3):281-293. [pmid: 12826990].
Johnson BA, Rosenthal N, Capece JA, Wiegand F, Mao L, Beyers K, et al. for the Topiramate for Alcoholism Advisory Board the Topiramate for Alcoholism Study Group. Topiramate for treating alcohol dependence: A randomized controlled trial. JAMA. 2007;298(14):1641-1651. [pmid: 17925516].
Kampman KM, Pettinati HM, Lynch KG, Whittingham T, Macfadden W, Dackis C, et al. A double-blind, placebo-controlled pilot trial of quetiapine for the treatment of Type A and Type B alcoholism. Journal of Clinical Psychopharmacology. 2007;27(4):344-351. [pmid: 17632217].
Karhuvaara S, Simojoki K, Virta A, Rosberg M, Löyttyniemi E, Nurminen T, et al. Targeted nalmefene with simple medical management in the treatment of heavy drinkers: A randomized double-blind placebo-controlled multicenter study. Alcoholism: Clinical and Experimental Research. 2007;31(7):1179-1187.
Kenna GA, McGeary JE, Swift RM. Pharmacotherapy, pharmacogenomics, and the future of alcohol dependence treatment, Part 1. American Journal of Health System Pharmacology. 2004a;61(21):2272-2279.
Kenna GA, McGeary JE, Swift RM. Pharmacotherapy, pharmacogenomics, and the future of alcohol dependence treatment, Part 2. American Journal of Health System Pharmacology. 2004b;61(22):2380-2388.
Kenna GA, Nielsen DM, Mello P, Schiesl A, Swift RM. Pharmacotherapy of dual substance abuse and dependence. CNS Drugs. 2007;21(3):213-237. [pmid: 17338593].
Kiefer F, Helwig H, Tarnaske T, Otte C, Wiedemann K. Pharmacological relapse prevention of alcoholism: Clinical predictors of outcome. European Addiction Research. 2005a;11(2):83-91. [pmid: 15785069].
Kiefer F, Jahn H, Wiedemann K. A neuroendocrinological hypothesis on gender effects of naltrexone in relapse prevention treatment. Pharmacopsychiatry. 2005b;38:184-186. [pmid: 16025425].
Kiefer F, Wiedemann K. Combined therapy: What does acamprosate and naltrexone combination tell us?. Alcohol & Alcoholism. 2004;39(6):542-547. [pmid: 15456690].
King AC, Volpicelli JR, Gunduz M, O’Brien CP, Kreek MJ. Naltrexone biotransformation and incidence of subjective side effects: A preliminary study. Alcoholism: Clinical and Experimental Research. 1997;21:906-909.
Kiritze-Topor P, Huas D, Rosenzweig C, Comte S, Paille F, Lehert P. A pragmatic trial of acamprosate in the treatment of alcohol dependence in primary care. Alcohol & Alcoholism. 2004;39(6):520-527. [pmid: 15304381].
Kranzler HR. Evidence-based treatments for alcohol dependence: New results and new questions. JAMA. 2006;295(17):2075-2076. [pmid: 16670416].
Kranzler HR, Modesto-Lowe V, Nuwayser ES. Sustained-release naltrexone for alcoholism treatment: A preliminary study. Alcoholism: Clinical and Experimental Research. 1998;22:1074-1079.
Kranzler HR, Modesto-Lowe V, Van Kirk J. Naltrexone vs. nefazodone for treatment of alcohol dependence: A placebo-controlled trial. Neuropsychopharmacology. 2000;22(5):493-503. [pmid: 10731624].
Kranzler HR, Van Kirk J. Efficacy of naltrexone and acamprosate for alcoholism treatment: A meta-analysis. Alcoholism: Clinical and Experimental Research. 2001;25:1335-1341.
Kranzler HR, Wesson DR, Billot L. for the DrugAbuse Sciences Naltrexone Depot Study Group. Naltrexone depot for treatment of alcohol dependence: A multicenter, randomized, placebo-controlled clinical trial. Alcoholism: Clinical and Experimental Research. 2004;28(7):1051-1059.
Kreek MJ, LaForge KS, Butelman E. Pharmacotherapy of addictions. Nature Reviews Drug Discovery. 2002;1:710-726.
Krystal JH, Cramer JA, Krol WF, Kirk GF, Rosenheck RA. for the Veterans Affairs Naltrexone Cooperative Study 425 Group. Naltrexone in the treatment of alcohol dependence. New England Journal of Medicine. 2001;345(24):1734-1739. [pmid: 11742047].
Kulig CC, Beresford TP. Hepatitis C in alcohol dependence: Drinking versus disulfiram. Journal of Addictive Diseases. 2005;24(2):77-89. [pmid: 15784525].
Laaksonen E, Koski-Jännes A, Salaspuro M, Ahtinen H, Alho H. 2007. A randomized, multicentre, open-label, comparative trial of disulfiram, naltrexone and acamprosate in the treatment of alcohol dependence. Retrieved December 5, 2007, from http://www.alcalc.oxfordjournals.org.
Ladewig D, Knecht T, Lehert P, Fendl A. Acamprosate: A stabilising factor in long-term withdrawal of alcoholic patients. Therapeutische Umschau. 1993;50:182-188. [pmid: 8475472].
Latt NC, Jurd S, Houseman J, Wutzke SE. Naltrexone in alcohol dependence: A randomized controlled trial of effectiveness in a standard clinical setting. Medical Journal of Australia. 2002;176:530-534. [pmid: 12064984].
Lesch OM, Walter H. Subtypes of alcoholism and their role in therapy. Alcohol & Alcoholism. 1996;1(Suppl):63-67. [pmid: 8737003].
Lhuintre JP, Daoust M, Moore ND, Chretien P, Saligaut C, Tran G, et al. Ability of calcium bis acetyl homotaurine, a GABA agonist, to prevent relapse in weaned alcoholics. Lancet. 1985;1(8436):1014-1016. [pmid: 2859465].
Lhuintre JP, Moore N, Tran G, Steru L, Langrenon S, Daoust M, et al. Acamprosate appears to decrease alcohol intake in weaned alcoholics. Alcohol and Alcoholism. 1990;25(6):613-622. [pmid: 2085344].
Litten RZ, Fertig J, Mattson M, Egli M. Development of medications for alcohol use disorders: Recent advances and ongoing challenges. Expert Opinion on Emerging Drugs. 2005;10:323-343. [pmid: 15934870].
Ma JZ, Ait-Daoud N, Johnson BA. Topiramate reduces the harm of excessive drinking: Implications for public health and primary care. Addiction. 2006;101(11):1561-1568. [pmid: 17034435].
Mann K. Pharmacotherapy of alcohol dependence: A review of the clinical data. CNS Drugs. 2004;18(8):485-504. [pmid: 15182219].
Mann K, Lehert P, Morgan MY. The efficacy of acamprosate in the maintenance of abstinence in alcohol-dependent individuals: Results of a meta­analysis. Alcoholism: Clinical and Experimental Research. 2004;28:51-63.
Mark TL, Kranzler HR, Poole VH, Hagen CA, McLeod C, Crosse S. Barriers to the use of medications to treat alcoholism. American Journal on Addictions. 2003a;12(4):281-294. [pmid: 14504021].
Mark TL, Kranzler HR, Song X. Understanding U.S. addiction physicians’ low rate of naltrexone prescription. Drug and Alcohol Dependency. 2003b;71(3):219-228.
Martin BK, Clapp L, Alfers J, Beresford TP. Adherence to court-ordered disulfiram at fifteen months: A naturalistic study. Journal of Substance Abuse Treatment. 2004;26(3):233-236. [pmid: 15063918].
Mason BJ. Treatment of alcohol-dependent outpatients with acamprosate: A clinical review. Journal of Clinical Psychiatry. 2001;62(Suppl 10):42-48. [pmid: 11584875].
Mason BJ. Acamprosate and naltrexone treatment for alcohol dependence: An evidence-based risk-benefits assessment. European Neuropsychopharmacology. 2003;13(6):469-475. [pmid: 14636963].
Mason BJ. Acamprosate in the treatment of alcohol dependence. Expert Opinions on Pharmacotherapy. 2005;6(12):2103-2115.
Mason BJ, Goodman AM, Chabac S, Lehert P. Effect of oral acamprosate on abstinence in patients with alcohol dependence in a double-blind, placebo-controlled trial: The role of patient motivation. Journal of Psychiatric Research. 2006;40:383-393. [pmid: 16546214].
Mason BJ, Goodman AM, Dixon RM, Hameed MH, Hulot T, Wesnes K, et al. A pharmacokinetic and pharmacodynamic drug interaction study of acamprosate and naltrexone. Neuropsychopharmacology. 2002;27(4):596-606. [pmid: 12377396].
McCarty D, Rieckmann T, Green C, Gallon S, Knudsen J. Training rural practitioners to use buprenorphine: Using The Change Book to facilitate technology transfer. Journal of Substance Abuse Treatment. 2004;26(3):203-208. [pmid: 15063914].
McCaul ME, Wand GS, Stauffer R, Lee SM, Rohde CA. Naltrexone dampens ethanol-induced cardiovascular and hypothalamic-pituitary-adrenal axis activation. Neuropsychopharmacology. 2001;25:537-547. [pmid: 11557167].
McGeary JE, Monti PM, Rohsenow DJ, Tidey J, Swift R, Miranda R. Genetic moderators of naltrexone’s effects on alcohol cue reactivity. Alcoholism: Clinical and Experimental Research. 2006;30(8):1288-1296.
Miller WR, Wilbourne PL. Mesa Grande: A methodological analysis of clinical trials of treatments for alcohol use disorders. Addiction. 2002;97(3):265-277. [pmid: 11964100].
Modesto-Lowe V. Naltrexone depot—DrugAbuse Sciences. IDrugs. 2002;5:835-838. [pmid: 12802700].
Monterosso JR, Flannery BA, Pettinati HM, Oslin DW, Rukstalis M, O’Brien CP, et al. Predicting treatment response to naltrexone: The influence of craving and family history. American Journal on Addictions. 2001;10(3):258-268. [pmid: 11579624].
Monti PM, Rohsenow DJ, Hutchison KE, Swift RM, Mueller TI, Colby SM, et al. Naltrexone’s effect on cue-elicited craving among alcoholics in treatment. Alcoholism: Clinical and Experimental Research. 1999;23(8):1386-1394.
Monti PM, Rohsenow DJ, Swift RM, Gulliver SB, Colby SM, Mueller TI, et al. Naltrexone and cue exposure with coping and communication skills training for alcoholics: Treatment process and 1-year outcomes. Alcoholism: Clinical and Experimental Research. 2001;25(11):1634-1147.
Morris PL, Hopwood M, Whelan G, Gardiner J, Drummond E. Naltrexone for alcohol dependence: A randomized controlled trial. Addiction. 2001;96(11):1565-1573. [pmid: 11784454].
Mueser KT, Noordsy DL, Fox L, Wolfe R. Disulfiram treatment for alcoholism in severe mental illness. American Journal on Addictions. 2003;12(3):242-252. [pmid: 12851020].
Myrick H. 2002. December. Pharmacotherapy of alcoholism: History and current perspectives. Symposium III: Pharmacotherapy of Alcoholism. Presentation at the American Academy of Addiction Psychiatry 13th Annual Meeting and Symposium. Las Vegas, NV.
Myrick H, Anton R. Recent advances in the pharmacotherapy of alcoholism. Current Psychiatry Reports. 2004;6:332-338. [pmid: 15355755].
Namkoong K, Lee BO, Lee PG, Choi MJ, Lee E. Acamprosate in Korean alcohol-dependent patients: A multi-centre, randomized, double-blind, placebo-controlled study. Alcohol and Alcoholism. 2003;38(2):135-141. [pmid: 12634260].
Niederhofer H, Staffen W. Comparison of disulfiram and placebo in treatment of alcohol dependence of adolescents. Drug and Alcohol Review. 2003;22(3):295-297. [pmid: 15385223].
O’Farrell TJ, Allen JP, Litten RZ. Disulfiram (Antabuse) contracts in treatment of alcoholism. NIDA Research Monograph 150. 1995:65-91. Rockville, MD. National Institute on Drug Abuse.
O’Malley SS, Froehlich JC. Advances in the use of naltrexone: An integration of preclinical and clinical findings. Recent Developments in Alcoholism. 2003;16:217-245. [pmid: 12638640].
O’Malley SS, Garbutt JC, Gastfriend DR, Dong Q, Kranzler HR. Efficacy of extended-release naltrexone in alcohol-dependent patients who are abstinent before treatment. Journal of Clinical Psychopharmacology. 2007a;27(5):507-512. [pmid: 17873686].
O’Malley SS, Jaffe AJ, Chang G, Schottenfeld RS, Meyer RE, Rounsaville B. Naltrexone and coping skills therapy for alcohol dependence: A controlled study. Archives of General Psychiatry. 1992;49:881-887. [pmid: 1444726].
O’Malley SS, Rounsaville BJ, Farren C, Namkoong K, Wu R, Robinson J, et al. Initial and maintenance naltrexone treatment for alcohol dependence using primary care vs. specialty care: A nested sequence of 3 randomized trials. Archives of Internal Medicine. 2003;163:1695-1704. [pmid: 12885685].
O’Malley SS, Sinha R, Grilo CM, Capone C, Farren CK, McKee SA, et al. Naltrexone and cognitive behavioral coping skills therapy for the treatment of alcohol drinking and eating disorder features in alcohol-dependent women: A randomized controlled trial. Alcoholism: Clinical and Experimental Research. 2007b;31(4):625-634.
Oslin D, Liberto JG, O’Brien J, Krois S. Tolerability of naltrexone in treating older alcohol-dependent patients. American Journal on Addictions. 1997a;6(3):266-270. [pmid: 9256993].
Oslin D, Liberto JG, O’Brien J, Krois S, Norbeck J. Naltrexone as an adjunctive treatment for older patients with alcohol dependence. American Journal of Geriatric Psychiatry. 1997b;5(4):324-332. [pmid: 9363289].
Oslin DW, Berrettini W, Kranzler HR, Pettinati H, Gelernter J, Volpicelli JR, et al. A functional polymorphism of the mu-opioid receptor gene is associated with naltrexone response in alcohol-dependent patients. Neuropsychopharmacology. 2003;28(8):1546-1552. [pmid: 12813472].
Oslin DW, Berrettini WH, O’Brien CP. Targeting treatments for alcohol dependence: The pharmacogenetics of naltrexone. Addiction Biology. 2006;11(3/4):397-403. [pmid: 16961767].
Paille FM, Guelfi JD, Perkins AC, Royer RJ, Steru L, Parot P. Double-blind randomized multicentre trial of acamprosate in maintaining abstinence from alcohol. Alcohol and Alcoholism. 1995;30(2):239-347. [pmid: 7662044].
Pelc I, Ansoms C, Lehert P, Fischer F, Fuch WJ, Landron F, et al. The European NEAT program: An integrated approach using acamprosate and psychosocial support for the prevention of relapse in alcohol-dependent patients with a statistical modeling of therapy success prediction. Alcoholism: Clinical and Experimental Research. 2002;26:1529-1538.
Pelc I Le Bon O Verbanck P Gavrilovic M Lion K Lehert P1992Calcium acetyl homotaurinate for maintaining abstinence in weaned alcoholic patients: A placebo controlled double-blind multi-centre study Naranjo C Sellers E Novel Pharmacological Interventions for Alcoholism 348 352 New York Springer Verlag
Pelc I, Verbanck P, Le Bon O, Gavrilovic M, Lion K, Lehert P. Efficacy and safety of acamprosate in the treatment of detoxified alcohol-dependent patients. British Journal of Psychiatry. 1997;170:73-77. [pmid: 9328500].
Petrakis IL. A rational approach to the pharmacotherapy of alcohol dependence. Journal of Clinical Psychopharmacology. 2006;26(Suppl 1):S3-S12. [pmid: 17114952].
Petrakis IL, Leslie D, Rosenheck R. Use of naltrexone in the treatment of alcoholism nationally in the Department of Veterans Affairs. Alcoholism: Clinical and Experimental Research. 2003;27:1780-1784.
Petrakis IL, Nich C, Ralevski E. Psychotic spectrum disorders and alcohol abuse: A review of pharmacotherapeutic strategies and a report on the effectiveness of naltrexone and disulfiram. Schizophrenia Bulletin. 2006a;32(4):644-654. [pmid: 16887890].
Petrakis IL, Poling J, Levinson C, Nich C, Carroll K, Ralevski E. Naltrexone and disulfiram in patients with alcohol dependence and comorbid post-traumatic stress disorder. Biological Psychiatry. 2006b;60(7):777-783. [pmid: 17008146].
Petrakis IL, Poling J, Levinson C, Nich C, Carroll K, Rounsaville B. Naltrexone and disulfiram in patients with alcohol dependence and comorbid psychiatric disorder. Biological Psychiatry. 2005;57:1128-1137. [pmid: 15866552].
Petrakis I, Ralevski E, Nich C, Levinson C, Carroll K, Poling J, Rounsaville B. the VA VISN I MIRECC Study Group. Naltrexone and disulfiram in patients with alcohol dependence and current depression. Journal of Clinical Psychopharmacology. 2007;27(2):160-165. [pmid: 17414239].
Pettinati HM, O’Brien CP, Rabinowitz AR, Wortman SM, Oslin DW, Kampman KM, et al. The status of naltrexone in the treatment of alcohol dependence: Specific effects on heavy drinking. Journal of Clinical Psychopharmacology. 2006;26(6):610-625. [pmid: 17110818].
Poldrugo F. Acamprosate treatment in a long-term community-based alcohol rehabilitation programme. Addiction. 1997;92(11):537-546.
Ray LA, Hutchison KE. Effects of naltrexone on alcohol sensitivity and genetic moderators of medication response: A double-blind placebo-controlled study. Archives of General Psychiatry. 2007;64(9):1069-1077. [pmid: 17768272].
Rohsenow DJ. What place does naltrexone have in the treatment of alcoholism?. CNS Drugs. 2004;18(9):547-560. [pmid: 15222772].
Rohsenow DJ, Miranda R, McGeary JE, Monti PM. Family history and antisocial traits moderate naltrexone’s effects on heavy drinking in alcoholics. Experimental and Clinical Psychopharmacology. 2007;15(3):272-281. [pmid: 17563214].
Rosenthal RN. Current and future drug therapies for alcohol dependence. Journal of Clinical Psychopharmacology. 2006;26(Suppl 1):S20-S29.
Roussaux JP, Hers D, Ferauge M. Does acamprosate diminish the appetite for alcohol in weaned alcoholics?. Journal of Pharmacy of Belgium. 1996;51(2):65-68.
Sass H, Soyka M, Mann K, Zieglgänsberger W. Relapse prevention by acamprosate: Results from a placebo-controlled study on alcohol dependence. Archives of General Psychiatry. 1996;53(8):673-680. [pmid: 8694680].
Scott LJ, Figgitt DP, Keam SJ, Waugh J. Acamprosate: A review of its use in the maintenance of abstinence in patients with alcohol dependence. CNS Drugs. 2005;19(5):445-464. [pmid: 15907154].
Sofuoglu M, Kosten TR. Pharmacologic management of relapse prevention in addictive disorders. Psychiatric Clinics of North America. 2004;27:627-648. [pmid: 15550284].
Soyka M, Chick J. Use of acamprosate and opioid agonists in the treatment of alcohol dependence: A European perspective. American Journal on Addictions. 2003;12(Suppl 1):S69-S80. [pmid: 14972781].
Soyka M, Preuss U, Schuetz C. Use of acamprosate and different kinds of psychosocial support in relapse prevention of alcoholism: Results from a non-blind, multicentre study. Drugs in Research and Development. 2002;3:1-12. [pmid: 11881521].
Srisurapanont M, Jarusuraisin N. Opioid antagonists for alcohol dependence (Review). Cochrane Database System Review Issue. 2005;2(1):CD001867.
Stewart SH, Connors GJ. Interest in pharmacotherapy and primary care alcoholism treatment among medically hospitalized, alcohol dependent patients. Journal of Addictive Diseases. 2007;26(2):63-69. [pmid: 17594999].
Streeton C, Whelan G. Naltrexone: A relapse prevention maintenance treatment of alcohol dependence: A meta-analysis of randomized controlled trials. Alcohol & Alcoholism. 2001;36:544-552. [pmid: 11704620].
Suh JJ, Pettinati HM, Kampman KM, O’Brien CP. The status of disulfiram: A half of a century later. Journal of Clinical Psychopharmacology. 2006;26(3):290-302. [pmid: 16702894].
Tambour S, Quertemont E. Preclinical and clinical pharmacology of alcohol dependence. Fundamental & Clinical Pharmacology. 2007;21:9-28. [pmid: 17227441].
Tempesta E, Janiri L, Bignamini A, Chabac S, Potgieter A. Acamprosate and relapse prevention in the treatment of alcohol dependence: A placebo-controlled study. Alcohol and Alcoholism. 2000;35(2):202-209. [pmid: 10787398].
Thomas CP, Wallack SS, Lee S, McCarty D, Swift R. Research to practice: Adoption of naltrexone in alcoholism treatment. Journal of Substance Abuse Treatment. 2003;24(1):1-11. [pmid: 12646325].
Thomas SE, Miller PM. Knowledge and attitudes about pharmacotherapy for alcoholism: A survey of counselors and administrators in community-based addiction treatment centres. Alcohol & Alcoholism. 2007;42(2):113-118. [pmid: 17172258].
Tiet QQ, Mausbach B. Treatments for patients with dual diagnosis: A review. Alcoholism: Clinical and Experimental Research. 2007;31(4):513-536.
Verheul R, Lehert P, Geerlings PJ, Koeter MW, van den Brink W. Predictors of acamprosate efficacy: Results from a pooled analysis of seven European trials including 1,485 alcohol-dependent patients. Psychopharmacology. 2005;178(2–3):167-173. [pmid: 15322728].
Volpicelli JR, Alterman AI, Hayashida M, O’Brien CP. Naltrexone in the treatment of alcohol dependence. Archives of General Psychiatry. 1992;49:876-880. [pmid: 1345133].
Volpicelli JR, Rhines KC, Rhines JS, Volpicelli LA, Alterman AI, O’Brien CP. Naltrexone and alcohol dependence: Role of subject compliance. Archives of General Psychiatry. 1997;54:737-742. [pmid: 9283509].
Weiss RD, Kueppenbender KD. Combining psychosocial treatment with pharmacotherapy for alcohol dependence. Journal of Clinical Psychopharmacology. 2006;26(Suppl 1):S37-S42. [pmid: 17114954].
Whitworth AB, Fischer F, Lesch OM, Nimmerrichter A, Oberbauer H, Platz T, et al. Comparison of acamprosate and placebo in long-term treatment of alcohol dependence. Lancet. 1996;347:1438-1442. [pmid: 8676626].
Willenbring ML. Medications to treat alcohol dependence: Adding to the continuum of care. JAMA. 2007;298(14):1691-1692. [pmid: 17925523].
Wright C IV, Vafier JA, Lake CR. Disulfiram-induced fulminating hepatitis: Guidelines for liver-panel monitoring. Journal of Clinical Psychiatry. 1988;49:430-434. [pmid: 3053669].
Yen MH, Ko HC, Tang FI, Lu RB, Hong JS. Study of hepatotoxicity of naltrexone in the treatment of alcoholism. Alcohol. 2006;38(2):117-120. [pmid: 16839858].