# What Is a TIP?

Treatment Improvement Protocols (TIPs), developed by the Center for Substance Abuse Treatment (CSAT), part of the Substance Abuse and Mental Health Services Administration (SAMHSA) within the U.S. Department of Health and Human Services (HHS), are best-practice guidelines for the treatment of substance use disorders. CSAT draws on the experience and knowledge of clinical, research, and administrative experts to produce TIPs, which are distributed to facilities and individuals across the country. As alcohol and drug use disorders are increasingly recognized as a major problem, the audience for TIPs is expanding beyond public and private treatment facilities to include practitioners in mental health, criminal justice, primary care, and other healthcare and social service settings.

## TIP Development Process

TIP topics are based on the current needs of substance abuse treatment professionals and other healthcare practitioners for information and guidance. After selecting a topic, CSAT invites staff from Federal agencies and national organizations to be members of a resource panel that reviews an initial draft prospectus and outline and recommends specific areas of focus as well as resources that should be considered in developing the content for the TIP. These recommendations are communicated to a consensus panel composed of experts on the topic who have been nominated by their peers. In partnership with Knowledge Application Program writers, consensus panel members participate in creating a draft document and then meet to review and discuss the draft. The information and recommendations on which they reach consensus form the foundation of the TIP. A panel chair ensures that the guidelines mirror the results of the group's collaboration.

A diverse group of experts closely reviews the draft document. Once the changes recommended by these field reviewers have been incorporated, the TIP is prepared for publication, in print and online. TIPs can be accessed via the Internet at http://www.kap.samhsa.gov.

Although each TIP strives to include an evidence base for the practices it recommends, CSAT recognizes that the field of substance abuse treatment is evolving, and research frequently lags behind the innovations pioneered in the field. A major goal of each TIP is to convey “frontline” information quickly but responsibly. For this reason, recommendations proffered in the TIP are based on either panelists' clinical experience or the literature.

## TIP Format

CSAT is embarking on a new approach to and format for TIPs:

- Most of the fundamental research that forms the evidence basis for a particular TIP is not provided in the TIP itself. Rather, those who wish to review the supporting research can access an annotated bibliography and literature review via the Internet at http://www.kap.samhsa.gov. These online resources include abstracts along with references; the online bibliography and literature review are updated every 6 months for 5 years after publication of the TIP.
- TIPs focus on how-to information. Coverage of topics is limited to what the audience needs to understand and use to improve treatment outcomes.
- TIPs increasingly use quick-reference tools such as tables and lists in lieu of extensive text discussion, making the information more readily accessible and useful for treatment providers.

## How TIP 49 Is Organized

This TIP, Incorporating Alcohol Pharmacotherapies Into Medical Practice, revises and expands on TIP 28, Naltrexone and Alcoholism Treatment, and includes discussion of the other medications currently approved for treating alcohol use disorders (AUDs). It provides the basic information, evidence- and consensus-based guidelines, tools, and resources necessary to help healthcare practitioners treat patients with AUDs.

Chapter 1 provides an overview of the use of medications to treat AUDs. Chapters 2 through 5 present detailed information about each medication:

- Chapter 2—Acamprosate
- Chapter 3—Disulfiram
- Chapter 4—Oral Naltrexone
- Chapter 5—Extended-Release Injectable Naltrexone.

Finally, Chapter 6 discusses factors to consider when treating patients with medications for AUDs. The appendices in the TIP provide handy resources for practitioners.