# Expert Advisory Board

- Randall T. Brown, M.D.
- Assistant Professor
- Department of Family Medicine
- University of Wisconsin School of Medicine and Public Health
- Madison, Wisconsin

- Dominic Ciraulo, M.D.
- Professor and Chairman
- Division of Psychiatry
- Boston University School of Medicine
- Boston, Massachusetts

- Scott M. Davis, M.D.
- Addiction Medicine Physician
- Inpatient Medical Services
- Betty Ford Center
- Rancho Mirage, California

- George Kolodner, M.D.
- CEO and Medical Director
- Kolmac Clinic
- Silver Spring, Maryland

- Henry Kranzler, M.D.
- Associate Scientific Director
- Alcohol Research Center
- University of Connecticut Health Center
- Farmington, Connecticut

- Robert J. Malcolm, Jr., M.D.
- Associate Dean and Attending Psychiatrist
- Institute of Psychiatry
- Medical University of South Carolina
- Charleston, South Carolina

- Barbara J. Mason, Ph.D.
- Professor
- Molecular and Integrative Neurosciences Department
- Scripps Research Institute
- La Jolla, California

- Richard N. Rosenthal, M.D.
- Chairman
- Department of Psychiatry
- St. Luke's Roosevelt Hospital Center
- New York, New York