# Consensus Panel

## Chair

- Eric C. Strain, M.D.
- Professor
- Department of Psychiatry and Behavioral Sciences
- Johns Hopkins University School of Medicine
- Baltimore, Maryland

## Consensus Panelists

- Adam J. Gordon, M.D., M.P.H.
- Assistant Professor
- Division of General Internal Medicine
- Department of Medicine
- University of Pittsburgh
- Pittsburgh, Pennsylvania

- Bankole A. Johnson, M.D., Ph.D., D.Sc.
- Chairman
- Department of Psychiatric Medicine
- University of Virginia Health System
- Charlottesville, Virginia

- Mary Elizabeth McCaul, Ph.D.
- Professor
- Department of Psychiatry and Behavioral Sciences
- Johns Hopkins School of Medicine
- Baltimore, Maryland

- Andrew Saxon, M.D.
- Professor of Psychiatry
- Department of Psychiatry and Behavioral Sciences
- University of Washington
- Seattle, Washington

- Robert Swift, M.D., Ph.D.
- Professor of Psychiatry and Human Behavior
- Brown University Medical School
- Center for Alcohol and Addiction Studies
- Providence, Rhode Island

- Allen Zweben, D.S.W.
- Professor and Associate Dean for Research and Sponsored Projects
- School of Social Work
- Columbia University
- New York, New York