# Appendix G—Acknowledgments

Numerous people contributed to the development of this TIP, including the TIP Consensus Panel, the Knowledge Application Program (KAP) Expert Advisory Board, the Resource Panel, and TIP Field Reviewers.

This publication was produced under KAP, a Joint Venture of The CDM Group, Inc., and JBS International, Inc. (JBS), for the Substance Abuse and Mental Health Services Administration, Center for Substance Abuse Treatment.

Lynne MacArthur, M.A., A.M.L.S., served as the JBS KAP Executive Project Co-Director, and Barbara Fink, RN, M.P.H., served as the JBS KAP Managing Project Co-Director. Other JBS KAP personnel included Candace Baker, M.S.W., MAC, Deputy Director for Product Development; Dennis Burke, M.S., M.A., TIPs, TAPs, and Other Products Manager; Elliott Vanskike, Ph.D., Senior Writer; Frances Nebesky, M.A., Quality Assurance Editor; and Wendy Caron, Quality Assurance Manager.