# Appendix F—Field Reviewers

- David D. Atkins, M.S.M., LISW, ACSW
- Alcohol/Substance Abuse Program Director
- Indian Health Service, Phoenix Area Office
- Phoenix, Arizona

- David A. Fiellin, M.D.
- Associate Professor of Medicine
- Yale University School of Medicine
- New Haven, Connecticut

- Sharon Morgillo Freeman, Ph.D., APRN-CS, MAC
- President, Center for Brief Therapy, P.C. and
- President, NAADAC, The Association for Addiction Professionals
- Fort Wayne, Indiana

- Monika A. Koch, M.D.
- Addiction Psychiatrist
- Chemical Dependence Recovery Program
- The Permanente Medical Group
- Vallejo, California

- Sandra C. Lapham, M.D., M.P.H.
- Director
- Behavioral Health Research Center of the Southwest
- Pacific Institute for Research and Evaluation
- Albuquerque, New Mexico

- Peter M. Miller, Ph.D.
- Professor
- Center for Drug and Alcohol Programs
- Medical University of South Carolina
- Charleston, South Carolina

- Paul Nagy, M.S., LPC, LCAS, CCS
- Program Director
- Duke Addictions Program
- Duke University Medical Center
- Durham, North Carolina

- Charles O'Brien, M.D., Ph.D.
- Professor
- Department of Psychiatry
- University of Pennsylvania School of Medicine
- Philadelphia, Pennsylvania

- Ashwin A. Patkar, M.D., MRC Psych
- Medical Director, Duke Addictions Program
- and
- Associate Professor, Division of Biological Psychiatry
- Department of Psychiatry and Behavioral Sciences
- Duke University Medical Center
- Durham, North Carolina

- James Recktenwald, M.S.W., CADC
- Substance Abuse Counselor
- Carl D. Perkins Vocational Training Center
- Thelma, Kentucky

- John Scanlon, D.O.
- Assistant Professor of Family Medicine and Addiction Medicine
- Pikeville College School of Osteopathic Medicine
- Pikeville, Kentucky

- Marvin D. Seppala, M.D.
- Medical Director and CEO
- Beyond Addictions
- Beaverton, Oregon

- C. Chapman Sledge, M.D., FASAM
- Medical Director
- Pine Grove Behavioral Health and Addiction Services
- Hattiesburg, Mississippi

- Ruth Robinson Staten, Ph.D., ARNP-CS
- Associate Professor
- University of Kentucky College of Nursing
- Lexington, Kentucky

- Scott H. Stewart, M.D.
- Center for Drug and Alcohol Programs
- Department of Psychiatry and Behavioral Sciences
- Medical University of South Carolina
- Charleston, South Carolina

- Daniel C. Vinson, M.D., M.S.P.H.
- Professor
- Department of Family and Community Medicine
- University of Missouri-Columbia
- Columbia, Missouri