# Appendix E—Resource Panel

- Patricia Allman
- Consultant
- Cephalon, Inc.
- Dillon Allman & Partners, LLC
- Bethesda, Maryland

- David R. Anderson
- Communications Director
- Ensuring Solutions to Alcohol Problems
- School of Public Health and Health Services
- The George Washington University
- Washington, D.C.

- Neil A. Capretto, D.O., FASAM
- Representing the National Association of Addiction Treatment Providers
- Medical Director
- Aliquippa, Pennsylvania

- Heidi L. Coleman, J.D.
- Chief
- Impaired Driving Division
- National Highway Traffic Safety Administration
- Washington, D.C.

- Carlo C. DiClemente, Ph.D.
- Representing the Division on Addictions, American Psychological Association
- Professor
- University of Maryland, Baltimore County
- Baltimore, Maryland

- Allyson T. Gage, Ph.D.
- Associate Director
- Central Nervous System Therapeutic Area
- Forest Research Institute
- Jersey City, New Jersey

- David R. Gastfriend, M.D.
- Vice President, Medical Affairs
- Alkermes, Inc.
- Cambridge, Massachusetts

- Beverley Goggins, RN, Ed.M.
- Representing Therapeutic Communities of America
- Lead Nurse
- Second Genesis, Inc.
- Silver Spring, Maryland

- George Kolodner, M.D.
- Representing the American Society of Addiction Medicine
- Director
- KOLMAC Clinic
- 1003 Spring Street
- Silver Spring, Maryland

- Stephen LeBlanc
- Public Health Analyst
- Consumer Affairs
- Office of the Director
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Cynthia Moreno-Tuohy, NCAC II, CCDC III
- Executive Director
- NAADAC, The Association for Addiction Professionals
- Alexandria, Virginia

- Charlotte A. Mullican, M.P.H.
- Senior Advisor for Mental Health Research
- Agency for Healthcare Research and Quality
- Rockville, Maryland

- Kevin P. Mulvey, Ph.D.
- Branch Chief
- Practice Assessment and Applications Branch
- Center for Substance Abuse Prevention
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Elyse Sharpe, LCSW-C
- Manager
- Work-Life Program
- Washington, D.C.

- Robert L. Stephenson II, M.P.H.
- Director
- Division of Workplace Programs
- Center for Substance Abuse Prevention
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Richard T. Suchinsky, M.D.
- Associate Chief for Addiction Disorders
- Department of Veterans Affairs
- Washington, D.C.

- Timothy P. Tunner, Ph.D., M.S.W.
- Senior Policy Associate—Behavioral Health
- National Association of Social Workers
- Washington, D.C.

- Allan Weber
- General Manager
- Odyssey Pharmaceuticals, Inc.
- East Hanover, New Jersey

- Wendy J. Wilcox
- American Association for Marriage and Family Therapy
- Bowie, Maryland

- Mark L. Willenbring, M.D.
- Director
- Treatment and Recovery Research Division
- National Institute on Alcohol Abuse and Alcoholism
- National Institutes of Health
- Bethesda, Maryland

- Stephen Wing, M.S.W.
- Associate Administrator for Alcohol Policy
- Division of Policy Coordination
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Wilbur Woodis, M.A.
- Division of Behavioral Health
- Indian Health Service
- Rockville, Maryland