# Appendix B—NIAAA's A Pocket Guide for Alcohol Screening and Brief Intervention

Included with permission from the National Institute on Alcohol Abuse and Alcoholism

[image]

[image]

[image]

[image]