# Appendix E. Field Reviewers

- Lonnetta Albright
- Director
- Great Lakes Addiction Technology Transfer Center
- University of Illinois
- Chicago, Illinois

- Thomas S. Baker, D.M., LPC
- Senior Consultant
- Employee Assistance
- Johnson & Johnson Corporate Headquarters
- New Brunswick, New Jersey

- Toni Barrett, M.A., CAP
- Senior Vice President of Programs
- Stewart-Marchman Center
- Daytona Beach, Florida

- Faye Belgrave, Ph.D.
- Professor of Psychology
- Virginia Commonwealth University
- Richmond, Virginia

- Thomas P. Beresford, M.D.
- Professor of Psychiatry
- University of Colorado Health Sciences Center
- Department of Veterans Affairs Medical Center
- Denver, Colorado

- Allan J. Cohen, M.A., MFT
- Director of Research and Development
- Aegis Medical Systems, Inc.
- Canoga Park, California

- Stephanie Covington, Ph.D.
- Consultant
- La Jolla, California

- Michael Cunningham, Ph.D., CDP
- Clinical Supervisor
- Triumph Treatment Services
- Yakima, Washington

- Dennis C. Daley, Ph.D.
- Chief, Addiction Medicine Service
- Associate Professor of Psychiatry
- Western Psychiatric Institute and Clinic
- Pittsburgh, Pennsylvania

- Philip Diaz, M.S.W.
- Chief Executive Office
- Gateway Community Services
- Jacksonville, Florida

- John Edwards, Ph.D.
- Family Therapy Trainer/Consultant
- Durham, North Carolina

- Marty Estrada
- Case Manager
- General Relief Team
- East County Intake and Eligibility Center
- Ventura, California

- Marvin E. Fangman, M.A., LMSW, ACADC
- Program Manager
- First Step: Mercy Recovery Center
- Mercy Medical Center
- Des Moines, Iowa

- Dorothy J. Farr, LSW, LADC
- Clinical Director
- Bucks County Drug and Alcohol Commission
- Warminster, Pennsylvania

- Michael T. Flaherty, Ph.D.
- Executive Director
- Institute for Research, Education and Training in Addictions
- Pittsburgh, Pennsylvania

- Cyrus V. Galyon, CAP
- Clinical Manager, Non-Residential Services
- Center for Drug-Free Living, Inc.
- Orlando, Florida

- Stephen J. Gumbley, M.A., ACDP II, LCDP
- Project Director
- Discovery House/Smart Management
- Providence, Rhode Island

- Diane E. Hague, M.S.S.W., LCSW, CADC
- Director
- Jefferson Alcohol and Drug Abuse Center
- Louisville, Kentucky

- James A. Hall, Ph.D., LISW
- Associate Professor of Pediatrics
- Roy J. and Lucille A. Carver College of Medicine
- University of Iowa
- Iowa City, Iowa

- Robin C. Halprin, Ph.D.
- Licensed Psychologist
- D.C. Department of Mental Health/CSA
- Washington, D.C.

- Martin Hernandez
- Administrative Assistant
- Ventura County Board of Supervisors, Third District
- Ventura, California

- Anne M. Herron, M.S., CRC, CASAC
- Director, Treatment Programming
- NYS Office of Alcoholism and Substance Abuse Services
- Albany, New York

- Sheryl D. Hunter, M.D.
- Massachusetts Mental Health Center
- Boston, Massachusetts

- Dick Jacobs, M.S., LMFT, CAP
- Chief Operating Officer
- Center for Drug-Free Living, Inc.
- Orlando, Florida

- Margaret M. Kotz, D.O.
- Addiction Psychiatrist
- Cleveland Clinic
- Cleveland, Ohio

- Roland C. Lamb
- Manager, Provider Network Administration
- Community Behavioral Health of Philadelphia's Behavioral Health System
- Philadelphia, Pennsylvania

- Kimberly A. Lucas, M.S., CADC
- Treatment Specialist
- Delaware Division of Substance Abuse and Mental Health
- New Castle, Delaware

- Thomas E. Lucking, M.A., Ed.S.
- Consultant
- Kalamazoo, Michigan

- Pierluigi Mancini, Ph.D., NCAC II
- Executive Director
- Clinic for Education, Treatment and Prevention of Addiction, Inc.
- (Hispanic Program)
- Atlanta, Georgia

- Michael J. McCann, M.A.
- Associate Director
- Matrix Institute on Addictions
- Los Angeles, California

- James R. McKay, Ph.D.
- Scientific Director
- Treatment Research Institute
- Philadelphia, Pennsylvania

- Cecilia McNamara, Ph.D.
- Health Science Administrator
- Behavioral Treatment Development Branch
- National Institute on Drug Abuse
- National Institutes of Health
- Bethesda, Maryland

- Alixe McNeil
- Assistant Vice President
- National Council on the Aging
- Washington, D.C.

- Terence McSherry, M.P.H., M.H.A.
- President and Chief Executive Officer
- Northeast Treatment Center
- Philadelphia, Pennsylvania

- Delinda Mercer, Ph.D.
- Treatment Research Center
- University of Pennsylvania
- Philadelphia, Pennsylvania

- Ethan Nebelkopf, Ph.D.
- Director
- Family and Child Guidance Clinic
- Native American Health Center
- Oakland, California

- Rhoda Olkin, Ph.D.
- Professor of Psychology
- California School of Professional Psychology
- Alameda, California

- David W. Oslin, M.D.
- Assistant Professor of Geriatric Psychiatry
- University of Pennsylvania
- Philadelphia, Pennsylvania

- Deborah J. Owens, M.S., LPC, CACD, CEAP
- Senior Consultant
- Employee Assistance Programs
- Fort Washington, Pennsylvania

- Lawrence Schonfeld, Ph.D.
- Professor of Aging and Mental Health
- Louis de la Parte Florida Mental Health Institute
- University of South Florida
- Tampa, Florida

- Harvey A. Siegal, Ph.D.
- Professor and Director
- Center for Interventions, Treatment, and Addictions Research
- Wright State University School of Medicine
- Dayton, Ohio

- Thomas M. Slaven, Ph.D., LPC
- Consulting Associate
- Duke University Medical Center
- Durham, North Carolina

- David Smith, M.D.
- Founder and Medical Director
- Haight-Ashbury Free Clinics
- Medical Director
- California Alcohol and Drug Programs
- San Francisco, California

- Antony P. Stephen, Ph.D., LCSW, RAS
- Executive Director
- Mental Health & Behavioral Serviced New Jersey Asian American Association for Human Services, Inc.
- Elizabeth, New Jersey

- Mary Ann Chutuape Stephens, Ph.D.
- Health Scientist Administrator
- Center for the Clinical Trials Network
- National Institute on Drug Abuse
- National Institutes of Health
- Bethesda, Maryland

- Erik Stone, M.S., CAC III
- Director of Compliance and Quality Improvement
- Signal Behavioral Health Network
- Denver, Colorado

- Kathy J. Stone, M.B.A., LMSW
- Associate Executive Director
- Magellan Behavioral Care of Iowa
- West Des Moines, Iowa

- Philip Toal, Ed.D., LMHC
- Clinical Manager, Non-Residential Services
- Center for Drug-Free Living, Inc.
- Orlando, Florida

- Tim Williams, M.S.W., LCSW
- Adult Services Director
- Orange, Person and Chatham Area Programs
- Carrboro, North Carolina

- Ann Yabusaki, Ph.D.
- Substance Abuse Director
- Coalition for a Drug-Free Hawaii
- Kaneohe, Hawaii