# Appendix C. Resource Panel

- James Callahan, D.P.A.
- Executive Vice President & CEO
- American Society of Addiction Medicine
- Chevy Chase, Maryland

- Caroline Cooper
- Associate Director
- Justice Programs Office
- School of Public Affairs
- American University
- Washington, D.C.

- Jennifer Edwards
- Assistant to the Director
- Corrections Program Office
- U.S. Department of Justice
- Washington, D.C.

- Jerry Flanzer, D.S.W., LCSW, CAC
- Social Science Analyst
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- National Institutes of Health
- Bethesda, Maryland

- Brenda Harding
- Public Health Advisor
- Division of State and Community Assistance
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Gil Hill
- Director, Office of Substance Abuse
- American Psychological Association
- Washington, D.C.

- Thomas F. Hilton, Ph.D.
- Program Official for Organization and Management Sciences Research
- Services Research Branch
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- National Institutes of Health
- Bethesda, Maryland

- Elizabeth (Beth) A. Peyton
- President
- Peyton Consulting
- Newark, New Jersey

- Barbara Ray
- Public Health Analyst
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Barbara Roberts, Ph.D.
- Senior Policy Analyst
- Office of Demand Reduction
- Office of National Drug Control Policy
- Executive Office of the President
- Washington, D.C.

- Mickey Smith
- Public Health Advisor
- Division of State and Community Assistance
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Richard T. Suchinsky, M.D.
- Associate Chief for Addictive Disorders and Psychiatric Rehabilitation
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.