# Appendix A. Bibliography

Addington J, el-Guebaly N. Group treatment for substance abuse in schizophrenia. Canadian Journal of Psychiatry. 1998;43(8):843-845.
Alcoholics Anonymous World Services. The A.A. Member—Medications and Other Drugs. New York: Alcoholics Anonymous World Services, 1991.
Allen, J.P., and Columbus, M., eds. Assessing Alcohol Problems: A Guide for Clinicians and Researchers. Treatment Handbook Series 4. NIH Publication No. 95-3723. Bethesda, MD: National Institute on Alcohol Abuse and Alcoholism, 1995.
Amass L, Kamien J.B. A tale of two cities: Financing two voucher programs for substance abusers through community donations. Experimental and Clinical Psychopharmacology. 2004;12(2):147-155. [pmid: 15122959].
American Academy of Pediatrics. Fetal alcohol syndrome alcohol-related neurodevelopmental disorders. Pediatrics. 2000;106:358-361. [pmid: 10920168].
American Indian Development Associates. Promising Practices and Strategies To Reduce Alcohol and Substance Abuse Among American Indians and Alaska Natives. Washington, DC: Office of Justice Programs, 2000.
American Medical Association. Role of Self-Help in Addiction Treatment. Res. 713, A-98. 1998.www.ama-assn.org/ama1/pub/upload/mm/388/referral_treatment.pdf[accessed April 26, 2004].
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, Third Edition, Revised (DSM-III-R). Washington, DC: American Psychiatric Association, 1987.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV). Washington, DC: American Psychiatric Association, 1994.
American Psychiatric Association. Practice Guidelines for Treatment of Patients With Substance Use Disorders: Alcohol, Cocaine, Opioids. Washington, DC: American Psychiatric Association, 1995.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition, Text Revision (DSM-IV-TR). Washington, DC: American Psychiatric Association, 2000.
American Psychological Association (APA). APA Rural Initiative: 1999 Year in Review. Washington, DC: APA, 1999.www.apa.org/rural/report99.html[accessed February 11, 2004].
American Society of Addiction Medicine. The effectiveness of social interventions for homeless substance abusers (special issue). Journal of Addictive Diseases 14(4), 1995.
American Society of Addiction Medicine. Relationship Between Treatment and Self Help: A Joint Statement of the American Society of Addiction Medicine and the American Academy of Addiction Psychiatry, 1997.http://www.asam.org/ppol/Treatment%20and%20Self%20Help.htm[accessed February 11, 2004].
Armstrong T.D, Costello E.J. Community studies on adolescent substance use, abuse, or dependence and psychiatric comorbidity. Journal of Consulting and Clinical Psychology. 2002;70:1224-1239. [pmid: 12472299].
Avants S.K, Margolin A, Kosten T.R, Rounsaville B.J, Schottenfeld R.S. When is less treatment better? The role of social anxiety in matching methadone patients to psychosocial treatments. Journal of Consulting and Clinical Psychology. 1998;66(6):924-931. [pmid: 9874905].
Barker, R.L. The Social Work Dictionary, Fourth Edition. Washington, DC: National Association of Social Workers, 1999.
Bartholomew N.G, Rowan-Szal G.A, Chatham L.R, Nucatola D.C, Simpson D.D. Sexual abuse among women entering methadone treatment. Journal of Psychoactive Drugs. 2002;34(4):347-354. [pmid: 12562102].
Bean, F.D.; Trejo, S.J.; Crapps, R.; and Tyler, M. The Latino Middle Class: Myth, Reality, and Potential. Los Angeles, CA: Tomás Rivera Policy Institute, 2001.
Beck, A.J., and Harrison, P.M. Prisoners in 2000. Bureau of Justice Statistics Bulletin. Washington, DC: Office of Justice Programs, August 2001. www.ojp.gov:80/bjs/abstract/p00.htm[accessed February 11, 2004].
Belenko S. Research on drug courts: A critical review, 1999 update. National Drug Court Institute Review. 1999;2(2):1-59.
Bell, P. Chemical Dependency and the African American: Counseling and Prevention Strategies, Second Edition. Center City, MN: Hazelden Publishing, 2002.
Beresford, T., and Gomberg, E., eds. Alcohol and Aging. New York: Oxford University Press, 1995.
Bigelow, G.E., and Silverman, K. Theoretical and empirical foundations of contingency management treatments for drug abuse. In: Higgins, S.T., and Silverman, K., eds. Motivating Behavior Change Among Illicit-Drug Abusers: Research on Contingency Management Interventions. Washington, DC: American Psychological Association, 1999, pp. 15–31.
Bixler, J.B., and Emery, B.D. Successful programs for individuals with co-occurring mental health and substance abuse disorders: Examples from five states. A Report of the Joint NASMHPD-NASADAD Task Force on Co-Occurring Mental Health and Substance Abuse Disorders. Alexandria, VA: National Association of State Mental Health Program Directors and National Association of State Alcohol and Drug Abuse Directors, 2000.
Bloom, F.; Owen, B.; and Covington, S. Gender-Responsive Strategies: Research, Practice, and Guiding Principles for Women Offenders. Washington, DC: National Institute of Corrections, June 2003.www.nicic.org/pubs/2003/018017.pdf[accessed February 11, 2004].
Blume, S.B. Understanding addictive disorders in women. In: Graham, A.W.; Shultz, T.K.; and Wilford, B.B., eds. Principles of Addiction Medicine, Second Edition. Chevy Chase, MD: American Society of Addiction Medicine, Inc., 1998, pp.1173–1190.
Bowser B.P, Bilal R. Drug treatment effectiveness: African-American culture in recovery. Journal of Psychoactive Drugs. 2001;33(4):391-402. [pmid: 11824698].
Boylin W.M, Doucette J. Multifamily therapy in substance abuse treatment with women. American Journal of Family Therapy. 1997;25(1):39-47.
Bradley B.P, Gossop M, Phillips G.T, Legarda J.J. The development of an opiate withdrawal scale (OWS). British Journal of the Addictions. 1987;82:1139-1142.
Brady K.T, Randall C.L. Gender differences in substance use disorders. Psychiatric Clinics of North America. 1999;22(2):241-252. [pmid: 10385931].
Brems C, Johnson M.E, Namyniuk L.L. Clients with substance abuse and mental health concerns: A guide for conducting intake interviews. Journal of Behavioral Health Services Research. 2002;29(3):327-334. [pmid: 12216376].
Brisbane, F.L. Introduction: Diversity among African Americans. In: Center for Substance Abuse Prevention (CSAP). Cultural Competence for Health Care Professionals Working With African-American Communities: Theory and Practice. CSAP Cultural Competence Series 7. DHHS Publication No. (SMA) 98–3238. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998, pp. 1–8.
Brochu S, Guyon L, Desjardins L. Comparative profiles of addicted adult populations in rehabilitation and correctional services. Journal of Substance Abuse Treatment. 1999;6(2):173-182. [pmid: 10023617].
Brown T.G, Seraganian P.J, Tremblay J, Annis H. Matching substance abuse aftercare treatments to client characteristics. Addictive Behavior. 2002;27:585-604.
Budney, A.J., and Higgins, S.T. A Community Reinforcement Plus Vouchers Approach: Treating Cocaine Addiction. Manual 2: Therapy Manuals for Drug Addiction Series. NIH Publication No. 98–4309. Rockville, MD: National Institute on Drug Abuse, 1998.
Bureau of Justice Assistance. Integrating Drug Testing Into a Pretrial Services System: 1999 Update. Washington, DC: Office of Justice Programs, July 1999. bja.ncjrs.org/publications/#1[accessed April 8, 2004].
Bureau of Justice Statistics. Correctional Populations in the United States, 1997. Washington, DC: Office of Justice Programs, November 2000. www.ojp.usdoj.gov/bjs/abstract/cpus97.htm[accessed February 11, 2004].
Busto U.E, Sykora K, Sellers E.M. A clinical scale to assess benzodiazepine withdrawal. Journal of Clinical Psychopharmacology. 1989;9:412-416. [pmid: 2574193].
Campbell, J.C. Prediction of homicide of and by battered women. In: Campbell, J.C., ed. Assessing Dangerousness: Violence by Sexual Offenders, Batterers, and Child Abusers. Thousand Oaks, CA: Sage Publications, 1995, pp. 96–113.
Carey K.B, Correia C.J. Severe mental illness and addictions: Assessment considerations. Addictive Behaviors. 1998;23(6):735-748. [pmid: 9801713].
Carroll, K.M. Integrating psychotherapy and pharmacotherapy in substance abuse treatment. In: Rodgers, F.; Keller, D.S.; and Morgenstern, J., eds. Treating Substance Abuse: Theory and Technique. New York: Guilford Press, 1996a, pp. 286–318.
Carroll K.M. Relapse prevention as a psychosocial treatment: A review of controlled clinical trials. Experimental and Clinical Psychopharmacology. 1996b;4(1):46-54.
Carroll, K.M. A Cognitive-Behavioral Approach: Treating Cocaine Addiction. Manual 1: Therapy Manuals for Drug Addiction Series. NIH Publication No. 94–4308. Rockville, MD: National Institute on Drug Abuse, 1998.
Carroll K.M, Nich C, Ball S.A, McCance E, Rounsaville B.J. Treatment of cocaine and alcohol dependence with psychotherapy and disulfiram. Addiction. 1998;93(5):713-727. [pmid: 9692270].
Catalano R.F, Gainey R.R, Fleming C.B, Haggerty K.P, Johnson N.O. An experimental intervention with families of substance abusers: One-year follow-up of the Focus on Families project. Addiction. 1999;94(2):241-254. [pmid: 10396792].
Catalano R.F, Haggerty K.P, Gainey R.R, Hoppe M. Reducing parental risk factors for children's substance misuses: Preliminary outcomes with opiate-addicted parents. Substance Use & Misuse. 1997;32(6):699-721. [pmid: 9178437].
Center for Substance Abuse Prevention. Substance Abuse Resource Guide: Asian and Pacific Islander Americans. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1996a. ncadi.samhsa/gov/govpubs/MS408[accessed March 4, 2004].
Center for Substance Abuse Prevention. Substance Abuse Resource Guide: Hispanic/Latino Americans. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1996b. www.ncadi.samhsa.gov/govpubs/MS441[accessed March 4, 2004].
Center for Substance Abuse Prevention. Communicating appropriately with Asian and Pacific Islander audiences. Technical Assistance Bulletin, June 1997. www.ncadi.samhsa.gov/govpubs/MS701[accessed February 11, 2004].
Center for Substance Abuse Prevention. Cultural Competence for Health Care Professionals Working With African-American Communities: Theory and Practice. Cultural Competence Series 7. DHHS Publication No. (SMA) 98–3238. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998a.
Center for Substance Abuse Prevention. Substance Abuse Resource Guide: American Indians and Alaska Natives. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998b. http://ncadi.samhsa.gov/referrals/resguides.aspx?InvNum=MS419[accessed March 4, 2004].
Center for Substance Abuse Prevention. Responding to Pacific Islanders: Culturally Competent Perspectives for Substance Abuse Prevention. Cultural Competence Series 8. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999.
Center for Substance Abuse Prevention. Substance Abuse Resource Guide: Lesbian, Gay, Bisexual, and Transgender Populations. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000. www.ncadi.samhsa.gov/referrals/resguides.aspx?InvNum=MS489[accessed February 11, 2004].
Center for Substance Abuse Prevention. Health Promotion and Substance Abuse Prevention Among American Indian and Alaska Native Communities: Issues in Cultural Competence. Cultural Competence Series 9. DHHS Publication No. (SMA) 99–3440. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001.
Centers for Disease Control and Prevention. Increasing morbidity and mortality associated with abuse of methamphetamine—United States 1991-1994. Morbidity and Mortality Weekly Report. 1995;44(47):882-886. [pmid: 7476843].
Centers for Disease Control and Prevention. HIV/AIDS Surveillance Report 14:1–48, 2002.
Centers for Disease Control and PreventionHIV/AIDS Surveillance Report 16:1–46, 2004.
Charney D.A, Paraherakis A.M, Gill K.J. Integrated treatment of comorbid depression substance use disorders. Journal of Clinical Psychiatry. 2001;62(9):672-677. [pmid: 11681761].
Chermack S.T, Walton M.A, Fuller B.E, Blow F.C. Correlates of expressed and received violence across relationship types among men and women substance abusers. Psychology of Addictive Behaviors. 2001;15(2):140-151. [pmid: 11419230].
Chick J, Lehert P, Landron F. Does acamprosate improve reduction of drinking as well as aiding abstinence?. Journal of Psychopharmacology. 2003;17(4):397-402. [pmid: 14870951].
Claus R.E, Kindleberger L.R. Engaging substance abusers after centralized assessment: Predictors of treatment entry and dropout. Journal of Psychoactive Drugs. 2002;34:25-31. [pmid: 12003110].
Cohen, M. Counseling Addicted Women: A Practical Guide. Thousand Oaks, CA: Sage Publications, 2000.
Compton W.M III, Cottler L.B, Phelps D.L, Ben Abdallah A, Spitznagel E.L. Psychiatric disorders among drug dependent subjects: Are they primary or secondary?. American Journal on Addictions. 2000;9(2):126-134. [pmid: 10934574].
Conner K.R, Shea R.R, McDermott M.P, Grolling R, Tocco R.V, Baciewicz G. The role of multifamily therapy in promoting retention in treatment of alcohol and cocaine dependence. American Journal on Addictions. 1998;7(1):61-73. [pmid: 9522008].
Connors G.J, Dermen K.H. Characteristics of participants in Secular Organizations for Sobriety (SOS). American Journal of Drug and Alcohol Abuse. 1996;22:281-295. [pmid: 8727060].
Connors, G.J.; Donovan, D.M.; and DiClemente, C.C. Substance Abuse Treatment and the Stages of Change: Selecting and Planning Interventions. New York: Guilford Press, 2001a.
Connors G.J, Tonigan J.S, Miller W.R. A longitudinal model of intake symptomatology AA participation and outcome: Retrospective study of the Project MATCH outpatient and aftercare samples. Journal of Studies on Alcohol. 2001b;62:817-825. [pmid: 11838919].
Cornish J.W, Metzger D, Woody G.E, Wilson D, McLellan A.T, Vandergrift B, O'Brien C.P. Naltrexone pharmacotherapy for opioid dependent federal probationers. Journal of Substance Abuse Treatment. 1997;14(6):529-534. [pmid: 9437624].
Covington, S. A Woman's Journey Home: Challenges for Female Offenders and Their Children. Washington, DC: Urban Institute, 2002.
Covington, S.S. A Woman's Way Through the Twelve Steps. Center City, MN: Hazelden Information Education, 1994.
Covington, S.S. Helping Women Recover: A Program for Treating Addiction. San Francisco: Jossey-Bass, 1999.
Covington, S.S. A Woman's Way Through the Twelve Steps Workbook. Center City, MN: Hazelden Information Education, 2000.
Coyhis D, White W.L. Addiction and recovery in Native America: Lost history, enduring lessons. Counselor. 2002;3(5):16-20.
Crnkovic A.E, DelCampo R.L. A systems approach to the treatment of chemical addiction. Contemporary Family Therapy. 1998;20(1):25-36.
Crowley, T.J. Research on contingency management treatment of drug dependence: Clinical implications and future directions. In: Higgins, S.T., and Silverman, K., eds. Motivating Behavior Change Among Illicit-Drug Abusers: Research on Contingency Management Interventions. Washington, DC: American Psychological Association, 1999, pp. 345–370.
CSAT (Center for Substance Abuse Treatment). Pregnant, Substance-Using Women. Treatment Improvement Protocol (TIP) Series 2. DHHS Publication No. (SMA) 95–3056. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1993a, reprinted 1995.
CSAT (Center for Substance Abuse Treatment). Screening for Infectious Diseases Among Substance Abusers. Treatment Improvement Protocol (TIP) Series 6. DHHS Publication No. (SMA) 93–2048. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1993b.
CSAT (Center for Substance Abuse Treatment). Assessment and Treatment of Cocaine-Abusing Methadone-Maintained Patients. Treatment Improvement Protocol (TIP) Series 10. DHHS Publication No. (SMA) 94–3004. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994a.
CSAT (Center for Substance Abuse Treatment). Assessment and Treatment of Patients With Coexisting Mental Illness and Alcohol and Other Drug Abuse. Treatment Improvement Protocol (TIP) Series 9. DHHS Publication No. (SMA) 94–2078. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994b.
CSAT (Center for Substance Abuse Treatment). Intensive Outpatient Treatment for Alcohol and Other Drug Abuse. Treatment Improvement Protocol (TIP) Series 8. DHHS Publication No. (SMA) 94–2077. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994c.
CSAT (Center for Substance Abuse Treatment). Practical Approaches in the Treatment of Women Who Abuse Alcohol and Other Drugs. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994d.
CSAT (Center for Substance Abuse Treatment). Screening and Assessment for Alcohol and Other Drug Abuse Among Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series 7. DHHS Publication No. (SMA) 94–2076. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994e.
CSAT (Center for Substance Abuse Treatment). Simple Screening Instruments for Outreach for Alcohol and Other Drug Abuse and Infectious Diseases. Treatment Improvement Protocol (TIP) Series 11. DHHS Publication No. (SMA) 94–2094. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994f.
CSAT (Center for Substance Abuse Treatment). Detoxification From Alcohol and Other Drugs. Treatment Improvement Protocol (TIP) Series 19. DHHS Publication No. (SMA) 95–3046. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995a.
CSAT (Center for Substance Abuse Treatment). Treating Alcohol and Other Drug Abusers in Rural and Frontier Areas: 1994 Award for Excellence Papers. Technical Assistance Publication (TAP) Series 17. DHHS Publication No. (SMA) 95–3054. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995b.
CSAT (Center for Substance Abuse Treatment). The Tuberculosis Epidemic: Legal and Ethical Issues for Alcohol and Other Drug Abuse Treatment Providers. Treatment Improvement Protocol (TIP) Series 18. DHHS Publication No. (SMA) 95–3047. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995c.
CSAT (Center for Substance Abuse Treatment). Bringing Excellence to Substance Abuse Services in Rural and Frontier America: 1996 Award for Excellence Papers. Technical Assistance Publication (TAP) Series 20. DHHS Publication No. (SMA) 97–3134. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1996.
CSAT (Center for Substance Abuse Treatment). A Guide to Substance Abuse Services for Primary Care Clinicians. Treatment Improvement Protocol (TIP) Series 24. DHHS Publication No. (SMA) 97–3139. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1997a.
CSAT (Center for Substance Abuse Treatment). Substance Abuse Treatment and Domestic Violence. Treatment Improvement Protocol (TIP) Series 25. DHHS Publication No. (SMA) 97–3163. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1997b.
CSAT (Center for Substance Abuse Treatment). Comprehensive Case Management for Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series 27. DHHS Publication No. (SMA) 98–3222. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998a.
CSAT (Center for Substance Abuse Treatment). Continuity of Offender Treatment for Substance Use Disorders From Institution to Community. Treatment Improvement Protocol (TIP) Series 30. DHHS Publication No. (SMA) 98–3245. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998b.
CSAT (Center for Substance Abuse Treatment). Naltrexone and Alcoholism Treatment. Treatment Improvement Protocol (TIP) Series 28. DHHS Publication No. (SMA) 98–3206. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998c.
CSAT (Center for Substance Abuse Treatment). Substance Abuse Among Older Adults. Treatment Improvement Protocol (TIP) Series 26. DHHS Publication No. (SMA) 98–3179. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998d.
CSAT (Center for Substance Abuse Treatment). Substance Use Disorder Treatment for People With Physical and Cognitive Disabilities. Treatment Improvement Protocol (TIP) Series 29. DHHS Publication No. (SMA) 98–3249. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998e.
CSAT (Center for Substance Abuse Treatment). Brief Interventions and Brief Therapies for Substance Abuse. Treatment Improvement Protocol (TIP) Series 34. DHHS Publication No. (SMA) 99–3353. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999a.
CSAT (Center for Substance Abuse Treatment). Cultural Issues in Substance Abuse Treatment. DHHS Publication No. (SMA) 99–3278. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999b.
CSAT (Center for Substance Abuse Treatment). Enhancing Motivation for Change in Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series 35. DHHS Publication No. (SMA) 99–3354. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999c.
CSAT (Center for Substance Abuse Treatment). Screening and Assessing Adolescents for Substance Use Disorders. Treatment Improvement Protocol (TIP) Series 31. DHHS Publication No. (SMA) 99–3282. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999d.
CSAT (Center for Substance Abuse Treatment). Treatment for Stimulant Use Disorders. Treatment Improvement Protocol (TIP) Series 33. DHHS Publication No. (SMA) 99–3296. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999e.
CSAT (Center for Substance Abuse Treatment). Treatment of Adolescents With Substance Use Disorders. Treatment Improvement Protocol (TIP) Series 32. DHHS Publication No. (SMA) 99–3283. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999f.
CSAT (Center for Substance Abuse Treatment). Integrating Substance Abuse Treatment and Vocational Services. Treatment Improvement Protocol (TIP) Series 38. DHHS Publication No. (SMA) 00–3470. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000a.
CSAT (Center for Substance Abuse Treatment). Substance Abuse Treatment for Persons With Child Abuse and Neglect Issues. Treatment Improvement Protocol (TIP) Series 36. DHHS Publication No. (SMA) 00–3357. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000b.
CSAT (Center for Substance Abuse Treatment). Substance Abuse Treatment for Persons With HIV/AIDS. Treatment Improvement Protocol (TIP) Series 37. DHHS Publication No. (SMA) 00–3410. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000c.
CSAT (Center for Substance Abuse Treatment). A Provider's Introduction to Substance Abuse Treatment for Lesbian, Gay, Bisexual, and Transgender Individuals. DHHS Publication No. (SMA) 01–3498. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001.
CSAT (Center for Substance Abuse Treatment). Clinical Guidelines for the Use of Buprenorphine in the Treatment of Opioid Addiction. Treatment Improvement Protocol (TIP) Series 40. DHHS Publication No. (SMA) 04–3939. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2004a.
CSAT (Center for Substance Abuse Treatment). The Confidentiality of Alcohol and Drug Abuse Patient Records Regulation and the HIPAA Privacy Rule: Implications for Alcohol and Substance Abuse Programs. DHHS Publication No. (SMA) 04-3947. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2004b. www.hipaa.samhsa.gov/download2/SAMHSAHIPAAComparisonClearedPDFVersion.pdf[accessed April 5, 2005].
CSAT (Center for Substance Abuse Treatment). Substance Abuse Treatment and Family Therapy. Treatment Improvement Protocol (TIP) Series 39. DHHS Publication No. (SMA) 04–3957. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2004c.
CSAT (Center for Substance Abuse Treatment). Acamprosate: A new medication for alcohol use disorders. Substance Abuse Treatment Advisory 4(1), 2005a.
CSAT (Center for Substance Abuse Treatment). Medication-Assisted Treatment for Opioid Addiction in Opioid Treatment Programs. Treatment Improvement Protocol (TIP) Series 43. DHHS Publication No. (SMA) 05-4048. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2005b.
CSAT (Center for Substance Abuse Treatment). Substance Abuse Relapse Prevention for Older Adults: A Group Treatment Approach. DHHS Publication No. 05-4053. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2005c.
CSAT (Center for Substance Abuse Treatment). Substance Abuse Treatment for Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series 44. DHHS Publication No. (SMA) 05–4056. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2005d.
CSAT (Center for Substance Abuse Treatment). Substance Abuse Treatment for Persons With Co-Occurring Disorders. Treatment Improvement Protocol (TIP) Series 42. DHHS Publication No. (SMA) 05–3922. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2005e.
CSAT (Center for Substance Abuse Treatment). Substance Abuse Treatment: Group Therapy. Treatment Improvement Protocol (TIP) Series 41. DHHS Publication No. (SMA) 05–3991. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2005f.
CSAT (Center for Substance Abuse Treatment). Client's Handbook: Matrix Intensive Outpatient Treatment for People With Stimulant Use Disorders. DHHS Publication No. (SMA) 06–4154. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2006a.
CSAT (Center for Substance Abuse Treatment). Client's Treatment Companion: Matrix Intensive Outpatient Treatment for People With Stimulant Use Disorders. DHHS Publication No. (SMA) 06–4155. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2006b.
CSAT (Center for Substance Abuse Treatment). Counselor's Family Education Manual: Matrix Intensive Outpatient Treatment for People With Stimulant Use Disorders. DHHS Publication No. (SMA) 06–4153. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2006c.
CSAT (Center for Substance Abuse Treatment). Counselor's Treatment Manual: Matrix Intensive Outpatient Treatment for People With Stimulant Use Disorders. DHHS Publication No. (SMA) 06–4152. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2006d.
CSAT (Center for Substance Abuse Treatment). Detoxification and Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series 45. DHHS Publication No. (SMA) 06–4131. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2006e.
CSAT (Center for Substance Abuse Treatment). Substance Abuse: Administrative Issues in Outpatient Treatment. Treatment Improvement Protocol (TIP) Series 46. DHHS Publication No. (SMA) 06–4151. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2006f.
CSAT (Center for Substance Abuse Treatment). Therapeutic Community Curriculum: Participant's Manual. DHHS Publication No. (SMA) 06-4122. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2006g.
CSAT (Center for Substance Abuse Treatment). Therapeutic Community Curriculum: Trainer's Manual. DHHS Publication No. (SMA) 06-4121. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2006h.
CSAT (Center for Substance Abuse Treatment). Improving Cultural Competence in Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, forthcoming a.
CSAT (Center for Substance Abuse Treatment). Substance Abuse Treatment: Addressing the Specific Needs of Women. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, forthcoming b.
da Costa C.L, Younes R.N, Lourenco M.T. Stopping smoking: A prospective randomized double-blind study comparing nortriptyline to placebo. Chest. 2002;122:403-408. [pmid: 12171809].
Daley, D.C. Relapse Prevention Workbook for Recovering Alcoholics and Drug Dependent Persons, Third Edition. Holmes Beach, FL: Learning Publications, 2001.
Daley, D.C. Dual Disorders: Relapse Prevention Workbook, Second Edition. Center City, MD: Hazelden Foundation, 2003.
Daley, D.C., and Marlatt, G.A. Managing Your Drug or Alcohol Problem: Therapist Guide. San Antonio, TX: Psychological Corporation, 1997.
Daley, D.C.; Marlatt, G.A.; and Spotts, C.E. Relapse prevention: Clinical models and specific intervention strategies. In: Graham, A.W.; Schultz, T.K.; Mayo-Smith, M.F.; Ries, R.K.; and Wilford, B.B., eds. Principles of Addiction Medicine, Third Edition. Chevy Chase, MD: American Society of Addiction Medicine, 2003, pp. 467–485.
Daley, D.C.; Mercer, D.; and Carpenter, G. Drug Counseling for Cocaine Addiction: The Collaborative Cocaine Treatment Study Manual. Manual 4: Therapy Manuals for Drug Addiction Series. NIH Publication No. 99–4380. Rockville, MD: National Institute on Drug Abuse, 1999.
Daley, D.C., and Thase, M.E. Dual Disorders Recovery Counseling: Integrated Treatment for Substance Use and Mental Health Disorders. Independence, MO: Independence Press, 2002.
D'Avanzo, C., and Geissler, E. Pocket Guide to Cultural Health Assessment, Third Edition. Mosby's Pocket Series. Philadelphia: Elsevier, 2003.
Deas D, Riggs P, Langenbucher J, Goldman M, Brown S. Adolescents are not adults: Developmental considerations in alcohol users. Alcoholism, Clinical and Experimental Research. 2000;24:232-237.
De La Rosa M. Acculturation and Latino adolescents' substance use: A research agenda for the future. Substance Use & Misuse. 2002;37(4):429-456. [pmid: 12064428].
De La Rosa M.R, White M.S. A review of the role of social support systems in the drug use behavior of Hispanics. Journal of Psychoactive Drugs. 2001;33(3):233-240. [pmid: 11718316].
De Leon G. Therapeutic communities for addictions: A theoretical framework. International Journal of the Addictions. 1995;30(12):1603-1645. [pmid: 8557410].
De Leon, G. The Therapeutic Community: Theory, Model, and Method. New York: Springer Publishing, 2000.
De Leon G, Jainchill N. Circumstance, motivation, readiness, and suitability as correlates of treatment tenure. Journal of Psychoactive Drugs. 1986;18:203-208. [pmid: 3772644].
De Leon G, Melnick G.D, Kressel D, Jainchill N. Circumstances, motivation, readiness and suitability (the CMRS Scales): Predicting retention in therapeutic community treatment. American Journal of Drug and Alcohol Abuse. 1994;20(4):495-515. [pmid: 7832182].
DiClemente C.C, Hughes S.O. Stages of change profiles in outpatient alcoholism treatment. Journal of Substance Abuse. 1990;2:217-235. [pmid: 2136111].
Ditton, P.M. Mental health and treatment of inmates and probationers. Bureau of Justice Statistics Special Report. Washington, DC: Office of Justice Programs, July 1999.www.ojp.usdoj.gov/bjs/abstract/mhtip.htm[accessed February 11, 2004].
Dixon L, McNary S, Lehman A. Remission of substance use disorder among psychiatric inpatients with mental illness. American Journal of Psychiatry. 1998;155(2):239-243. [pmid: 9464204].
Drake R.E, Essock S.M, Shaner A, Carey K.B, Minkoff K, Kola L, Lynde D, Osher F.C, Clark R.E, Rickards L. Implementing dual diagnosis services for clients with severe mental illness. Psychiatric Services. 2001;52:469-476. [pmid: 11274491].
Drake R.E, McHugo G.J, Clark R.E, Teague G.B, Xie H, Miles K, Ackerson T.H. Assertive community treatment for patients with co-occurring severe mental illness and substance use disorder: A clinical trial. American Journal of Orthopsychiatry. 1998a;68(2):201-215. [pmid: 9589759].
Drake R.E, Mercer-McFadden C, Mueser K.T, McHugo G.J, Bond G.R. Review of integrated mental health substance abuse treatment for patients with dual disorders. Schizophrenia Bulletin. 1998b;24(4):589-608. [pmid: 9853791].
Drake R.E, Mueser K.T. Psychosocial approaches to dual diagnosis. Schizophrenia Bulletin. 2000;26:105-118. [pmid: 10755672].
Edwards, J.T. Treating Chemically Dependent Families: A Practical Systems Approach for Professionals. Minneapolis, MN: Johnson Institute, 1990.
Edwards M.D, Steinglass P. Family therapy treatment outcomes for alcoholism. Journal of Marital and Family Therapy. 1995;21(4):475-509.
Ehrman R.N, Robbins S.J, Cornish J.W. Results of a baseline urine test predict levels of cocaine use during treatment. Drug and Alcohol Dependence. 2001;62(1):1-7. [pmid: 11173162].
Eisen M, Keyser-Smith J, Dampeer J, Sambrano S. Evaluation of substance use outcomes in demonstration projects for pregnant and postpartum women and their infants: Findings from a quasi-experiment. Addictive Behaviors. 2000;25(1):123-129. [pmid: 10708327].
Epstein E.E, McCrady B.S. Behavioral couples treatment of alcohol and drug use disorders: Current status and innovations. Clinical Psychology Review. 1998;18(6):689-711. [pmid: 9779329].
Epstein, J.; Barker, P.; Vorburger, M.; and Murtha, C. Serious Mental Illness and Its Co-Occurrence With Substance Use Disorders, 2002. Analytic Series A-24. DHHS Publication No. (SMA) 04–3905. Rockville, MD: Office of Applied Studies, Substance Abuse and Mental Health Services Administration, 2004.www.oas.samhsa.gov/CoD/Cod.htm lsqb;accessed August 17, 2004].
Evans, K., and Sullivan, J.M. Dual Diagnosis: Counseling the Mentally Ill Substance Abuser, Second Edition. New York: Guilford Press, 2000.
Fals-Stewart W, Birchler G.R. A national survey of the use of couples therapy in substance abuse treatment. Journal of Substance Abuse Treatment. 2001;20:277-283. [pmid: 11672643].
Fals-Stewart W, Birchler G.R, O'Farrell T.J. Behavioral couples therapy for male substance-abusing patients: Effects on relationship adjustment drug-using behavior. Journal of Consulting and Clinical Psychology. 1996;64:959-972. [pmid: 8916625].
Farabee D, Prendergast M, Anglin M.D. The effectiveness of coerced treatment for drug-abusing offenders. Federal Probation. 1998;62:3-10.
Farabee D, Prendergast M, Cartier J, Wexler H, Knight K, Anglin M.D. Barriers to implementing effective correctional drug treatment programs. Prison Journal. 1999;79:150-162.
Farabee D, Rawson R, McCann M. Adoption of drug avoidance activities among patients in contingency management and cognitive-behavioral treatments. Journal of Substance Abuse Treatment. 2002;23(4):343-350. [pmid: 12495796].
Fears, D. A Diverse—and Divided—Black Community. Washington Post, February 24, 2002, pp. A1, A8.
Festinger D.S, Lamb R.J, Marlowe D.B, Kirby K.C. From telephone to office: Intake attendance as a function of appointment delay. Addictive Behaviors. 2002;27(1):131-137. [pmid: 11800219].
Finnegan, D.G., and McNally, E.B. Counseling Lesbian, Gay, Bisexual, and Transgender Substance Abusers: Dual Identities, Second Edition. Binghamton, NY: Haworth Press, 2002.
Finney, J.W.; Hahn, A.C.; and Moos, R.H. The effectiveness of inpatient and outpatient treatment for alcohol abuse: The need to focus on mediators and moderators of setting effects. Addiction 91(12):1773–1796; discussion 1803–1820, 1996.
Fiorentine R. After drug treatment: Are 12-Step programs effective in maintaining abstinence?. American Journal of Drug and Alcohol Abuse. 1999;25(1):93-116. [pmid: 10078980].
First, M.B.; Spitzer, R.L.; Gibbon, M.; and Williams, J.B.W. Structured Clinical Interview for DSM-IV Axis I Disorders (SCID-I), Clinician Version. Washington, DC: American Psychiatric Association, 1997.
Fishman H.C, Andes F. Enhancing family therapy: The addition of a community resource specialist. Journal of Marital and Family Therapy. 2001;27(1):111-116. [pmid: 11215980].
Fishman J, Reynolds T, Riedel E. A retrospective investigation of an intensive outpatient substance abuse treatment program. American Journal of Drug and Alcohol Abuse. 1999;25(2):185-196. [pmid: 10395154].
Flynn P.M, Craddock S.G, Luckey J.W, Hubbard R.L, Dunteman G.H. Comorbidity of antisocial personality and mood disorders among psychoactive substance-dependent treatment clients. Journal of Personality Disorders. 1996;10(1):56-67.
Folstein M.F, Folstein S.E, McHugh P.R. Mini-Mental State: A practical method for grading the cognitive state of patients for the clinician. Journal of Psychiatric Research. 1975;12:189-198. [pmid: 1202204].
Forman, R. One AA meeting doesn't fit all: Six keys to prescribing 12-Step programs. Current Psychiatry, October 2002, pp. 1, 10, 16–24.
Frank E, Winkleby M.A, Altman D.G, Rockhill B, Fortmann S.P. Predictors of physician's smoking cessation advice. JAMA. 1991;266:3139-3144. [pmid: 1956100].
Fudala P.J, Yu E, MacFadden W, Boardman C, Chiang C.N. Effects of buprenorphine and naloxone in morphine-stabilized opioid addicts. Drug and Alcohol Dependence. 1998;50:1-8. [pmid: 9589267].
Fuller R.K, Gordis E. Refining the treatment of alcohol withdrawal: Editorial. JAMA. 1994;272:557-558. [pmid: 8046812].
Gastfriend, D.R. Placement matching: Challenges and technical progress. In: Proceedings: Tenth Annual Meeting & Symposium, December 2–5, 1999. Prairie Village, KS: American Academy of Addiction Psychiatry, 1999, pp. 18–19.www.aaap.org/meetings/proceedings.pdf[accessed February 11, 2004].
Gaston L. Reliability and criterion-related validity of the California Psychotherapy Alliance Scales—patient version. Psychological Assessment. 1991;3:68-74.
Gfroerer J, Penne M, Pemberton M, Folsom R. Substance abuse treatment need among older adults in 2020: The impact of the aging baby-boom cohort. Drug and Alcohol Dependence. 2003;69(2):127-135. [pmid: 12609694].
Glaze, L.E. Probation and parole in the United States, 2002. Bureau of Justice Statistics Bulletin. Washington, DC: Office of Justice Programs, August 2003.www.ojp.usdoj.gov/bjs/pub/pdf/ppus02.pdf[accessed February 11, 2004].
Gloria A.M, Peregoy J.J. Counseling Latino alcohol and other substance users/abusers: Cultural considerations for counselors. Journal of Substance Abuse Treatment. 1996;13:119-126. [pmid: 8880669].
Glover E.D, Glover P.N, Payne T.J. Treating nicotine dependence. American Journal of the Medical Sciences. 2003;326(4):183-186. [pmid: 14557731].
Godlaski T.M, Leukefeld C, Cloud R. Recovery: With and without self-help. Substance Use & Misuse. 1997;32(5):621-627. [pmid: 9141180].
Godley, S.H.; Meyers, R.J.; Smith, J.E.; Karvinen, T.; Titus, J.C.; Godley, M.D.; Dent, G.; Passetti, L.; and Kelberg, P. The Adolescent Community Reinforcement Approach for Adolescent Cannabis Users. Cannabis Youth Treatment Series, Volume 4. DHHS Publication No. (SMA) 01–3489. Rockville, MD: Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, 2001.
Goldenberg, I., and Goldenberg, H. Family Therapy: An Overview, Second Edition. Brooks Grove, CA: Brooks/Cole Publishing Co., 1985.
Goodman D. Arab Americans and American Muslims express mental health needs. SAMHSA News. 2002;10(1):2-3.
Gorski, T.T. The CENAPS^®^ model of relapse prevention therapy (CMRPT^®^). In: Carroll, K.M., ed. Approaches to Drug Abuse Counseling. NIH Publication No. 00–4151. Rockville, MD: National Institute on Drug Abuse, 2000, pp. 23–38.
Gorski, T.T., and Kelley, J.M. Counselor's Manual for Relapse Prevention With Chemically Dependent Criminal Offenders. Technical Assistance Publication (TAP) Series 19. DHHS Publication No. (SMA) 96–3115. Rockville, MD: Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, 1996.
Gorski, T.T.; Kelley, J.M.; Havens, L.; and Peters, R.H. Relapse Prevention and the Substance-Abusing Criminal Offender. Technical Assistance Publication (TAP) Series 8. DHHS Publication No. (SMA) 95–3071. Rockville, MD: Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, 1993, reprinted 1995.
Gottheil E, Weinstein S.P, Sterling R.C, Lundy A, Serota R.D. A randomized controlled study of the effectiveness of intensive outpatient treatment for cocaine dependence. Psychiatric Services. 1998;49(6):782-787. [pmid: 9634157].
Greenfeld, L.A., and Snell, T.L. Women offenders. Bureau of Justice Statistics Special Report. Washington, DC: Office of Justice Programs, December 1999, revised October 2000.www.ojp.usdoj.gov/bjs/abstract/wo.htm[accessed February 11, 2004].
Greenwood G.L, White E.W, Page-Shafer K, Bein E, Osmond D.H, Paul J, Stall R.D. Correlates of heavy substance use among young gay and bisexual men: The San Francisco Young Men's Health Study. Drug and Alcohol Dependence. 2001;61(2):105-112. [pmid: 11137274].
Gregoire T.K, Snively C.A. The relationship of social support and economic self-sufficiency to substance abuse outcomes in a long-term recovery program for women. Journal of Drug Education. 2001;31(3):221-237. [pmid: 11696960].
Grella C.E, Polinsky M.L, Hser Y.-I, Perry S.M. Characteristics of women-only and mixed-gender drug abuse treatment programs. Journal of Substance Abuse Treatment. 1999;17:37-44. [pmid: 10435251].
Grieco, E.M. The Native Hawaiian and other Pacific Islander population: 2000. Census 2000 Brief. C2KBR/01-14. Washington, DC: U.S. Census Bureau, 2001.
Grosenick J.K, Hatmaker C.M. Perceptions of the importance of physical setting in Substance abuse treatment. Journal of Substance Abuse Treatment. 2000;18:29-39. [pmid: 10636604].
Gruber K, Chutuape M.A, Stitzer M.L. Reinforcement-based intensive outpatient treatment for inner city opiate abusers: A short-term evaluation. Drug and Alcohol Dependence. 2000;57:211-223. [pmid: 10661672].
Guardia J, Caso C, Arias F, Gual A, Sanahuja J, Ramirez M, Mengual I, Gonzalvo B, Segura L, Trujols J, Casas M.A. double-blind placebo-controlled study of naltrexone in the treatment of alcohol-dependence disorder: Results from a multicenter trial. Alcoholism, Clinical and Experimental Research. 2002;26(9):1381-1387.
Guss, J.R., ed. Addictions in the Gay and Lesbian Community. New York: Haworth Press, 2000.
Guydish J, Sorensen J.L, Chan M, Werdegar D, Bostrom A, Acampora A. A randomized trial comparing day and residential drug abuse treatment: 18-month outcomes. Journal of Consulting and Clinical Psychology. 1999;67(3):428-434. [pmid: 10369064].
Guydish J, Werdegar D, Sorensen J.L, Clark W, Acampora A. Drug abuse day treatment: A randomized clinical trial comparing day and residential treatment programs. Journal of Consulting and Clinical Psychology. 1998;66(2):280-289. [pmid: 9583331].
Hadjicostandi J, Cheurprakobkit S. Drugs and substances: Views from a Latino community. American Journal of Drug and Alcohol Abuse. 2002;28(4):693-710. [pmid: 12492265].
Hamilton, N.L.; Brantley, L.B.; Tims, F.M.; Angelovich, N.; and McDougall, B. Family Support Network for Adolescent Cannabis Users. Cannabis Youth Treatment Series, Volume 3. DHHS Publication No. (SMA) 01–3488. Rockville, MD: Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, 2001.
Harrison, P.M., and Beck, A.J. Prisoners in 2002. Bureau of Justice Statistics Bulletin. Washington, DC: Office of Justice Programs, July 2003.www.ojp.usdoj.gov/bjs/pub/pdf/p02.pdf[accessed February 11, 2004].
Hasin D.S, Trautman K.D, Miele G.M, Samet S, Smith M, Endicott J. Psychiatric Research Interview for Substance and Mental Disorders (PRISM): Reliability for substance abusers. American Journal of Psychiatry. 1996;153:1195-1201. [pmid: 8780425].
Health Resources and Services Administration. Cultural Competence Works: Using Cultural Competence To Improve the Quality of Health Care for Diverse Populations and Add Value to Managed Care Arrangements. Washington, DC: U.S. Department of Health and Human Services, 2001.
Heather N, Luce A, Peck D, Dunbar B, James I. Development of a treatment version of the Readiness to Change Questionnaire. Addiction Research. 1999;7:63-68.
Heather N, Rollnick S, Bell A. Predictive validity of the Readiness to Change Questionnaire. Addiction. 1993;88:1667-1677. [pmid: 8130706].
Higgins S.T. Some potential contributions of reinforcement and consumer-demand theory to reducing cocaine use. Addictive Behaviors. 1996;21(6):803-816. [pmid: 8904945].
Higgins, S.T. Introduction. In: Higgins, S.T., and Silverman, K., eds. Motivating Behavior Change Among Illicit-Drug Abusers: Research on Contingency Management Interventions. Washington, DC: American Psychological Association, 1999, pp. 3–13.
Higgins S.T, Budney A.J, Bickel W.K, Foerg F.E, Ogden D, Badger G.J. Outpatient behavioral treatment for cocaine dependence: One year outcomes. Experimental and Clinical Psychopharmacology. 1995;3:205-212.
Higgins, S.T., and Silverman, K., eds. Motivating Behavior Change Among Illicit-Drug Abusers: Research on Contingency Management Interventions. Washington, DC: American Psychological Association, 1999.
Higgins S.T, Wong C.J, Badger G.J, Ogden D.E, Dantona R.L. Contingent reinforcement increases cocaine abstinence during outpatient treatment and 1 year of follow-up. Journal of Consulting and Clinical Psychology. 2000;68(1):64-72. [pmid: 10710841].
Hodgins D.C, el-Guebaly N, Addington J. Treatment of substance abusers: Single or mixed gender programs. Addiction. 1997;92(7):805-812. [pmid: 9293039].
Hoffman F. Cultural adaptations of Alcoholics Anonymous to serve Hispanic populations. International Journal of Addiction. 1994;29(4):445-460.
Hoffman, J.A.; Jones, B.; Caudill, B.D.; Mayo, D.W.; and Mack, K.A. The living in balance counseling approach. In: Carroll, K.M., ed. Approaches to Drug Abuse Counseling. NIH Publication No. 00–4151. Rockville, MD: National Institute on Drug Abuse, 2000, pp. 39–60.
Hoffmann, N.G.; Halikas, J.A.; Mee-Lee, D.; and Weedman, R.D. Patient Placement Criteria for the Treatment of Psychoactive Substance Use Disorders. Chevy Chase, MD: American Society of Addiction Medicine, 1991.
Howell E.M, Heiser N, Harrington M. A review of recent findings on substance abuse treatment for pregnant women. Journal of Substance Abuse Treatment. 1999;16:195-219. [pmid: 10194738].
Hser Y.I, Polinsky M.L, Maglione M, Anglin M.D. Matching clients' needs with drug treatment services. Journal of Substance Abuse Treatment. 1999;16(4):299-305. [pmid: 10349602].
Hubbard J.R, Everett A.S, Khan M.A. Alcohol and drug abuse in patients with physical disabilities. American Journal of Drug Abuse. 1996;22(2):215-231.
Humphreys K, Moos R.H, Cohen G. Social and community resources and long-term recovery from treated and untreated alcoholism. Journal of Alcoholism Studies. 1997;58:231-238.
Hurt R.D, Offord K.P, Croghan I.T, Gomez-Dahl L, Kottke T.E, Morse M.E, Melton L.J III. Mortality following inpatient addictions treatment: Role of tobacco use in a community-based cohort. JAMA. 1996;275:1097-1103. [pmid: 8601929].
Inciardi, J.A. A Corrections-Based Continuum of Effective Drug Abuse Treatment: Research Preview. Washington, DC: National Institute of Justice, U.S. Department of Justice, June 1996.
Institute of Medicine. Bridging the Gap Between Practice and Research: Forging Partnerships With Community-Based Drug and Alcohol Treatment. Washington, DC: National Academy Press, 1998.
Irvin J.E, Bowers C.A, Dunn M.E, Wang M.C. Efficacy of relapse prevention: A meta-analytic review. Journal of Consulting and Clinical Psychology. 1999;67:563-570. [pmid: 10450627].
Jaffe J.H, O'Keefe C. From morphine clinics to buprenorphine: Regulating opioid agonist treatment of addiction in the United States. Drug and Alcohol Dependence. 2003;70:S3-S11. [pmid: 12738346].
Jainchill N. Substance dependency treatment for adolescents: Practice and research. Substance Use & Misuse. 2000;35(1214):2031-2060. [pmid: 11138716].
Jezewski, M.A., and Sotnik, P. Culture Brokering: Providing Culturally Competent Rehabilitation Services to Foreign-Born Persons. Buffalo, NY: Center for International Rehabilitation Research Information and Exchange, 2001.www.cirrie.buffalo.edu/cbrokering.html[accessed February 11, 2004].
Joe G.W, Simpson D.D, Broome K.M. Effects of readiness for drug abuse treatment on client retention and assessment of process. Addiction. 1998;93:1177-1190. [pmid: 9813899].
Johnson K.M, Beale C.L. The rural rebound. Wilson Quarterly. 1998;22(2):16-27.
Johnson J.L, Leff M. Children of substance abusers: Overview of research findings. Pediatrics. 1999;103:1085-1099. [pmid: 10224196].
Johnson R.E, McCagh J.C. Buprenorphine and naloxone for heroin dependence. Current Psychiatry Reports. 2000;2:519-526. [pmid: 11123005].
Johnson R.E, Strain E.C, Amass L. Buprenorphine: How to use it right. Drug and Alcohol Dependence. 2003;70:S59-S77. [pmid: 12738351].
Jordan L.C, Davidson W.S, Herman S.E, Boots Miller B.J. Involvement in 12-Step programs among persons with dual diagnoses. Psychiatric Services. 2002;53:894-896. [pmid: 12096178].
Joyner L.M, Wright J.D, Devine J.A. Reliabilit and validity of the Addiction Severity Index among homeless substance misusers. Substance Use & Misuse. 1996;31(6):729-751. [pmid: 8816118].
Kadden, R.; Carroll, K.M.; Donovan, D.; Cooney, N.; Monti, P.; Abrams, D.; Litt, M.; and Hester, R., eds. Cognitive-Behavioral Coping Skills Therapy Manual: A Clinical Research Guide for Therapists Treating Individuals With Alcohol Abuse and Dependence. Project MATCH Monograph Series, Volume 3. NIH Publication No. 94–3724. Bethesda, MD: National Institute on Alcohol Abuse and Alcoholism, 1995.
Kandel D.B, Johnson J.G, Bird H.R, Weissman M.M, Goodman S.H, Lahey B.B, Regier D.A, Schwab-Stone M.E. Psychiatric comorbidity among adolescents with substance use disorders: Findings from the MECA study. Journal of the American Academy of Child and Adolescent Psychiatry. 1999;38:693-699. [pmid: 10361787].
Karageorge, K. Mental Health Status of Male and Female Clients Before and After Substance Abuse Treatment. NEDS Fact Sheet 135. Fairfax, VA: National Evaluation Data Services, 2002.
Katz E.C, Gruber K, Chutuape M.A, Stitzer M.L. Reinforcement-based outpatient treatment for opiate and cocaine abusers. Journal of Substance Abuse Treatment. 2001;20(1):93-98. [pmid: 11239734].
Kavanagh, K., and Kennedy, P.H. Promoting Cultural Diversity: Strategies for Health Care Professionals. Thousand Oaks, CA: Sage Publications, 1992.
Kelly J.F, McKellar J.D, Moos R. Major depression in patients with substance use disorders: Relationship to 12-Step self-help involvement and substance use outcomes. Addiction. 2003;98(4):499-508. [pmid: 12653819].
Kelly R.C, Mieczkowski T, Sweeney S.A. Hair analysis for drugs of abuse. Hair color and race differentials or systematic differences in drug preferences?. Forensic Science International. 2000;107(1–3):63-86. [pmid: 10689562].
Kessler R.C, Nelson C.B, McGonagle K.A, Edlund M.H, Frank R.G, Leaf P.J. The epidemiology of co-occurring addictive and mental disorders: Implications for prevention service utilization. American Journal of Orthopsychiatry. 1996;66(1):17-31. [pmid: 8720638].
Kirby, K.C.; Amass, L.; and McLellan, A.T. Disseminating contingency management research to drug abuse treatment practitioners. In: Higgins, S.T., and Silverman, K., eds. Motivating Behavior Change Among Illicit-Drug Abusers: Research on Contingency Management Interventions. Washington, DC: American Psychological Association, 1999a, pp. 327–344.
Kirby K.C, Marlowe D.B, Festinger D.S, Garvey K.A, LaMonaca V. Community reinforcement training for family and significant others of drug abusers: A unilateral intervention to increase treatment entry of drug users. Drug and Alcohol Dependence. 1999b;56:85-96. [pmid: 10462097].
Kirby K.C, Marlowe D.B, Festinger D.S, Lamb R.J, Platt J.J. Schedule of voucher delivery influences initiation of cocaine abstinence. Journal of Consulting and Clinical Psychology. 1998;66(5):761-767. [pmid: 9803694].
Kohn C.S, Tsoh J.Y, Weisner C.M. Changes in smoking status among substance abusers: Baseline characteristics and abstinence from alcohol and drugs at 12-month follow-up. Drug and Alcohol Dependence. 2003;69:61-71. [pmid: 12536067].
Korper, S.P., and Council, C.L., eds. Substance Use by Older Adults: Estimates of Future Impact on the Treatment System. Analytic Series A-21. DHHS Publication No. (SMA) 03–3763. Rockville, MD: Office of Applied Studies, Substance Abuse and Mental Health Services Administration, 2002.
Kremer D, Malkin M.J, Benshoff J.J. Physical activity programs offered in substance abuse treatment facilities. Journal of Substance Abuse Treatment. 1995;12:327-333. [pmid: 8583515].
Krestan, J.-A., ed. Bridges to Recovery: Addiction, Family Therapy, and Multicultural Treatment. New York: Free Press, 2000.
Krystal J.H, Cramer J.A, Krol W.F, Kirk G.F, Rosenheck R.A. Naltrexone in the treatment of alcohol dependence. New England Journal of Medicine. 2001;345(24):1734-1739. [pmid: 11742047].
Kurasaki, K.S.; Okazaki, S.; and Sue, S., eds. Asian American Mental Health: Assessment Theories and Methods. New York: Plenum, 2002.
Kus, R.J., ed. Addiction and Recovery in Gay and Lesbian Persons. New York: Haworth Press, 1995.
Laken M.P, Ager J.W. Effects of case management on retention in prenatal substance abuse treatment. American Journal of Drug and Alcohol Abuse. 1996;22:439-448. [pmid: 8841690].
Laken M.P, McComish J.F, Ager J. Predictors of prenatal substance use and birth weight during outpatient treatment. Journal of Substance Abuse Treatment. 1997;14:359-366. [pmid: 9368212].
Langan N.P, Pelissier B.M. Gender differences among prisoners in drug treatment. Journal of Substance Abuse. 2001;13:291-301. [pmid: 11693453].
LaPlante, M.P.; Kennedy, J.; Kaye, H.S.; and Wenger, B.L. Disability and employment. Disability Statistics Abstract. Number 11. San Francisco: Disability Statistics Center, 1996.www.dsc.ucsf.edu/pdf/abstract11.pdf[accessed February 11, 2004].
Latimer W.W, Winters K.C, D'Zurilla T, Nichols M. Integrated family and cognitive-behavioral therapy for adolescent substance abusers: A stage I efficacy study. Drug and Alcohol Dependence. 2003;71(3):303-317. [pmid: 12957348].
Laudet A, Magura S, Furst R.T, Kumar N. Male partners of substance-abusing women in treatment: An exploratory study. American Journal of Drug and Alcohol Abuse. 1999;25(4):607-627. [pmid: 10548438].
Laudet, A.; Magura, S.; Vogel, H.; and Knight, E. Twelve Month Follow-up on Members of a Dual Recovery Self-help Program. Poster presented at the 128th Annual Meeting of the American Public Health Association, Boston, November 2000a.
Laudet A.B, Magura S, Vogel H.S, Knight E. Recovery challenges among dually diagnosed individuals. Journal of Substance Abuse Treatment. 2000b;18(4):321-329. [pmid: 10812304].
La Veist, T.A.; Diala, C.; and Jarrett, N.C. Social status and perceived discrimination: Who experiences discrimination in the health care system, how, and why? In: Hogue, C.J.R.; Hargraves, M.A.; and Collins, K.S., eds. Minority Health in America. Baltimore: Johns Hopkins University Press, 2000, pp. 194–208.
Lawental E, McLellan A.T, Grissom G, Brill P, O'Brien C.P. Coerced treatment for substance abuse problems detected through workplace urine surveillance: Is it effective?. Journal of Substance Abuse. 1996;8(1):115-128. [pmid: 8743772].
Legal Action Center. Steps to Success: Helping Women With Alcohol and Drug Problems Move From Welfare to Work. New York: Legal Action Center, 1999.
Leonhard C, Mulvey K, Gastfriend D.R, Shwartz M. The Addiction Severity Index: A field study of internal consistency and validity. Journal of Substance Abuse Treatment. 2000;18(2):129-135. [pmid: 10716096].
Liddle H.A. Theory development in a family-based therapy for adolescent drug abuse. Journal of Clinical Child Psychology. 1999;28(4):521-532. [pmid: 10587903].
Liddle, H.A. Multidimensional Family Therapy for Adolescent Cannabis Users. Cannabis Youth Treatment Series, Volume 5. DHHS Publication No. (SMA) 02–3660. Rockville, MD: Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, 2002.
Liddle H.A, Dakof G.A, Parker K, Diamond G.S, Barrett K, Tejeda M. Multidimensional family therapy for adolescent drug abuse: Results of a randomized clinical trial. American Journal of Drug and Alcohol Abuse. 2001;27(4):651-688. [pmid: 11727882].
Ling W, Charuvastra C, Collins J.F, Batki S, Brown L.S Jr., Kintaudi P, Wesson D.R, McNicholas L, Tusel D.J, Malkerneker U, Renner J.A Jr., Santos E, Casadonte P, Fye C, Stine S, Wang R.I, Segal D. Buprenorphine maintenance treatment of opiate dependence: A multicenter randomized clinical trial. Addiction. 1998;93(4):475-486. [pmid: 9684386].
Longabaugh R, Wirtz P.W, Zweben A, Stout R.L. Network support for drinking Alcoholics Anonymous and long-term matching effects. Addiction. 1998;93:1313-1333. [pmid: 9926538].
Loustaunau, M.O., and Sobo, E.J. The Cultural Context of Health, Illness, and Medicine. Westport, CT: Bergin & Garvey, 1997.
Macdonald, D.I., and Kaplan, D.J. The role of the substance abuse professional. In: Graham, A.W.; Schultz, T.K.; Mayo-Smith, M.F.; Ries, R.K.; and Wilford, B.B., eds. Principles of Addiction Medicine, Third Edition. Chevy Chase, MD: American Society of Addiction Medicine, 2003, pp. 987–992.
Magerl, H., and Schulz, E. Methods of Saliva Analysis and the Relationship Between Saliva and Blood Concentration. Paper presented at 13th International Conference on Alcohol, Drugs and Traffic Safety, Adelaide, Australia, August 13–18, 1995.www.druglibrary.org/schaffer/Misc/driving/s3p1.htm[accessed February 11, 2004].
Magura S, Laudet A.B, Mahmood D, Rosenblum A, Vogel H.S, Knight E.L. Role of self-help processes in achieving abstinence among dually diagnosed persons. Addictive Behaviors. 2003;28(3):399-413. [pmid: 12628615].
Magura S, Nwakeze P.C, Rosenblum A, Joseph H. Substance misuse and related infectious diseases in a soup kitchen population. Substance Use & Misuse. 2000;35(4):551-583. [pmid: 10741541].
Mann K, Lehert P, Morgan M.Y. The efficacy of acamprosate in the maintenance of abstinence in alcohol-dependent individuals: Results of a meta-analysis. Alcoholism, Clinical and Experimental Research. 2004;28(1):51-63.
Marlatt, G.A., and Gordon, J.R., eds. Relapse Prevention: Maintenance Strategies in the Treatment of Addictive Behaviors. New York: Guilford Press, 1985.
Marlatt, G.A., and Kristeller, J.L. Mindfulness and meditation. In: Miller, W.M., ed. Integrating Spirituality Into Treatment: Resources for Practitioners. Washington, DC: American Psychological Association, 1999.
Marlowe D.B, DeMatteo D.S, Lamb R.J, Festinger D.S. A sober assessment of drug courts. Federal Sentencing Reporter. 2003;16(2):153-157.
Marlowe D.B, Husband S.D, Lamb R.J, Kirby K.C, Iguchi M.Y, Platt J.J. Psychiatric comorbidity in cocaine dependence. American Journal on Addictions. 1995;4:70-81.
Marlowe D.B, Kirby K.C, Bonieskie L.M, Glass D.J, Dodds L.D, Husband S.D, Platt J.J, Festinger D.S. Assessment of coercive and noncoercive pressures to enter drug abuse treatment. Drug and Alcohol Dependence. 1996;42(2):77-84. [pmid: 8889406].
Marsh J.C, D'Aunno T.A, Smith B.D. Increasing access and providing social services to improve drug abuse treatment for women with children. Addiction. 2000;95:1237-1247. [pmid: 11092071].
Martin, C.S., and Winters, K.C. Diagnosis and assessment of alcohol use disorders among adolescents. Alcohol Health and Research World 22:95–105, 1998.http://pubs.niaaa.nih.gov/publications/arh22-2/95-106.pdf[accessed March 3, 2004].
Martin D.J, Garske J.P, Davis M.K. Relation of the therapeutic alliance with outcome and other variables: A meta-analytic review. Journal of Consulting and Clinical Psychology. 2000;68:438-450. [pmid: 10883561].
Martino S, Carroll K.M, O'Malley S.S, Rounsaville B.J. Motivational interviewing with psychiatrically ill substance abusing patients. American Journal on Addictions. 2000;9(1):88-91. [pmid: 10914297].
Maruschak, L.M. HIV in prisons, 2000. Bureau of Justice Statistics Bulletin. Washington, DC: Office of Justice Programs, October 2002, revised February 2003.www.ojp.usdoj.gov/bjs/abstract/hivp00.htm[accessed February 11, 2004].
Matrix Center. The Matrix Model of Outpatient Chemical Dependency Treatment: Family Education Guidelines and Handouts. Los Angeles: The Matrix Center, 1989.
McCaul M.E, Svikis D.S, Moore R.D. Predictors of outpatient treatment retention: Patient versus substance use characteristics. Drug and Alcohol Dependence. 2001;62(1):9-17. [pmid: 11173163].
McCrady, B.S. Recent research in twelve step programs. In: Graham, A.W.; Schultz, T.K.; and Wilford, B.B, eds. Principles of Addiction Medicine, Second Edition. Chevy Chase, MD: American Society of Addiction Medicine, 1998, pp. 707–717.
McCrady B.S, Epstein E.E, Hirsch L.S. Maintaining change after conjoint behavioral alcohol treatment for men: Outcomes at 6 months. Addiction. 1999;94(9):1381-1396. [pmid: 10615723].
McCrady, B.S., and Miller, W.R., eds. Research on Alcoholics Anonymous: Opportunities and Alternatives. New Brunswick, NJ: Rutgers Center of Alcohol Studies, 1993.
McKay J.R, Alterman A.I, Cacciola J.S, Rutherford M.J, O'Brien C.P, Koppenhaver J. Group counseling versus individualized relapse prevention aftercare following intensive outpatient treatment for cocaine dependence: Initial results. Journal of Consulting and Clinical Psychology. 1997;65(5):778-788. [pmid: 9337497].
McKay J.R, Alterman A.I, Rutherford M.J. The relationship of alcohol use to cocaine relapse in cocaine dependent patients in an aftercare study. Journal of Studies on Alcohol. 1999;60(2):176-180. [pmid: 10091955].
McKay J.R, Lynch K.G, Shepard D.S, Pettinati H.M. The effectiveness of telephone-based continuing care for alcohol and cocaine dependence: 24-month outcomes. Archives of General Psychiatry. 2005;62(2):199-207. [pmid: 15699297].
McKinnon, J. The Black population in the United States: March 2002. Current Population Reports. P20–541. Washington, DC: U.S. Census Bureau, 2003.
McLellan A.T, Cacciola J, Kushner H, Peters R, Smith I, Pettinati H. The fifth edition of the Addiction Severity Index: Cautions additions and normative data. Journal of Substance Abuse Treatment. 1992a;9:461-480.
McLellan A.T, Hagan T.A, Levine M, Gould F, Meyers K, Bencivengo M, Durell J. Supplemental social services improve outcomes in public addiction treatment. Addiction. 1998;93:1489-1499. [pmid: 9926553].
McLellan A.T, Hagan T.A, Levine M, Meyers K, Gould F, Bencivengo M, Durell J, Jaffee J. Does clinical case management improve outpatient addiction treatment?. Drug and Alcohol Dependence. 1999;55:91-103. [pmid: 10402154].
McLellan A.T, Hagan T.A, Meyers K, Randall M, Durell J. “Intensive” outpatient substance abuse treatment: Comparisons with “traditional” outpatient treatment. Journal of Addictive Diseases. 1997;16(2):57-84. [pmid: 9083825].
McLellan A.T, Kushner H, Metzger D. The fifth edition of the Addiction Severity Index. Journal of Substance Abuse Treatment. 1992b;9:199-213. [pmid: 1334156].
McLellan A.T, Lewis D.C, O'Brien C.P, Kleber H.D. Drug dependence a chronic medical illness: Implications for treatment, insurance and outcomes evaluation. JAMA. 2000;284(13):1689-1695. [pmid: 11015800].
Mee-Lee, D., and Shulman, G.D. The ASAM placement criteria and matching patients to treatment. In: Graham, A.W.; Schultz, T.K.; Mayo-Smith, M.F.; Ries, R.K.; and Wilford, B.B., eds. Principles of Addiction Medicine, Third Edition. Chevy Chase, MD: American Society of Addiction Medicine, 2003, pp. 453–465.
Mee-Lee, D.; Shulman, G.D.; Callahan, J.F.; Fishman, M.; Gastfriend, D.; Hartman, R.; and Hunsicker, R.J., eds. Patient Placement Criteria for the Treatment of Substance-Related Disorders: Second Edition-Revised (PPC-2R). Chevy Chase, MD: American Society of Addiction Medicine, 2001.
Meezan W, O'Keefe M. Multifamily group therapy: Impact on family functioning and child behavior. Families in Society. 1998;79(1):32-44.
Meissen G, Powell T.J, Wituk S.A, Girrens K, Arteaga S. Attitudes of AA contact persons toward group participation by persons with a mental illness. Psychiatric Services. 1999;50(8):1079-1081. [pmid: 10445659].
Mendelson J, Jones R.T. Clinical and pharmacological evaluation of buprenorphine and naloxone combinations: Why the 4:1 ratio for treatment. Drug and Alcohol Dependence. 2003;70:S29-S37. [pmid: 12738348].
Mendelson J, Jones R.T, Welm S, Baggott M, Fernandez I, Melby A.K, Nath R.P. Buprenorphine and naloxone combinations: The effects of three dose ratios in morphine-stabilized opiate-dependent volunteers. Psychopharmacology. 1999;141:37-46. [pmid: 9952063].
Mercer, D. Description of an addiction counseling approach. In: Carroll, K.M., ed. Approaches to Drug Abuse Counseling. NIH Publication No. 00–4151. Rockville, MD: National Institute on Drug Abuse, 2000, pp. 81–90.
Mercer, D., and Woody, G.E. An Individual Drug Counseling Approach to Treating Cocaine Addiction: The Collaborative Cocaine Treatment Study Model. Manual 3: Therapy Manuals for Drug Addiction. NIH Publication No. 99–4380. Rockville, MD: National Institute on Drug Abuse, 1999.
Merikangas K.R, Mehta R.L, Molnar B.E, Walters E.E, Swendsen J.D, Aguilar-Gaziola S, Bijl R, Borges G, Caraveo-Anduaga J.J, Dewitt D.J, Kolody B, Vega W.A, Wittchen H.-U, Kessler R.C. Comorbidity of substance use disorders with mood and anxiety disorders: Results of the international consortium in psychiatric epidemiology. Addictive Behaviors. 1998;23:893-907. [pmid: 9801724].
Metsch L.R, McCoy C.B. Drug treatment experiences: Rural and urban comparisons. Substance Use & Misuse. 1999;34(4&5):763-784. [pmid: 10210104].
Meyers R.J, Miller W.R, Hill D.E, Tonigan J.S. Community reinforcement and family training (CRAFT): Engaging unmotivated drug users in treatment. Journal of Substance Abuse. 1998;10:291-308. [pmid: 10689661].
Meyers R.J, Miller W.R, Smith J.E, Tonigan J.S. A randomized trial of two methods for engaging treatment-refusing drug users through concerned significant others. Journal of Consulting and Clinical Psychology. 2002;70:1182-1185. [pmid: 12362968].
Meyers R.J, Smith J.E, Lash D.N. The community reinforcement approach. Recent Developments in Alcoholism. 2003;16:183-195. [pmid: 12638638].
Mid-America Addiction Technology Transfer Center (MATTC). Psychotherapeutic Medications 2003: What Every Counselor Should Know. Kansas City, MO: MATTC, 2000.www.134.193.108.18/MATTC/information/mattcProds.asp[accessed February 11, 2004].
Mieczkowski, T., and Newel, R. Patterns of concordance between hair assays and urinalysis for cocaine: Longitudinal analysis of probationers in Pinellas County, Florida. In: Harrison, L., and Hughes, A., eds. Validity of Self-Reported Drug Use: Improving the Accuracy of Survey Estimates. NIDA Research Monograph 167. NTIS Publication No. 97–4147. Rockville, MD: National Institute on Drug Abuse, 1997, pp. 161–199.
Mieczkowski T, Newel R, Wraight B. Using hair analysis urinalysis and self-reports to estimate drug use in a sample of detained juveniles. Substance Use & Misuse. 1998;33(7):1547-1567. [pmid: 9657415].
Miele G.M, Carpenter K.M, Cockerham M.S, Trautman K.D, Blaine J, Hasin D.S. Substance Dependence Severity Scale (SDSS): Reliability and validity of a clinician-administered interview for DSM-IV substance use disorders. Drug and Alcohol Dependence. 2000;59:63-75. [pmid: 10706976].
Milby J.B, Schumacher J.E, Raczynski J.M, Caldwell E, Engle M, Michael M, Carr J. Sufficient conditions for effective treatment of substance abusing homeless persons. Drug and Alcohol Dependence. 1996;43:39-47. [pmid: 8957141].
Miller, B.A. Partner violence experiences and women's drug use: Exploring the connections. In: Wetherington, C.L., and Roman, A.B., eds. Drug Addiction Research and the Health of Women. Rockville, MD: National Institute on Drug Abuse, 1998, pp. 407–416.
Miller, M.M. Traditional approaches to the treatment of addiction. In: Graham, A.W.; Schultz, T.K.; and Wilford, B.B, eds. Principles of Addiction Medicine, Second Edition. Chevy Chase, MD: American Society of Addiction Medicine, 1998, pp. 315–326.
Miller N.S, Ninonuero F.G, Klamen D.L, Hoffmann N.G, Smith D.E. Integration of treatment and posttreatment variables in predicting results of abstinence-based outpatient treatment after one year. Journal of Psychoactive Drugs. 1997;29(3):239-248. [pmid: 9339855].
Miller, W.R., and Rollnick, S. Motivational Interviewing: Preparing People for Change, Second Edition. New York: Guilford Press, 2002.
Miller, W.R., and Sanchez, V.C. Motivating young adults for treatment and lifestyle change. In: Howard, G.S., and Nathan, P.E., eds. Alcohol Use and Misuse by Young Adults. Notre Dame, IN: University of Notre Dame Press, 1994, pp. 55–81.
Miller W.R, Tonigan J.S. Assessing drinkers' motivation to change: The States of Change Readiness and Treatment Eagerness Scale (SOCRATES). Psychology of Addictive Behaviors. 1996;10(2):81-89.
Miller, W.R.; Tonigan, J.S.; and Montgomery, H.A. Assessment of Client Motivation for Change: Preliminary Validation of the SOCRATES (Rev.) Instrument. Albuquerque, NM: University of New Mexico, 1990.
Minkoff K. An integrated treatment model for dual diagnosis of psychosis and addiction. Hospital and Community Psychiatry. 1989;40(10):1031-1036. [pmid: 2807203].
Minkoff K. Models for addiction treatment in psychiatric populations. Psychiatric Annals. 1994;24(8):412-417.
Minkoff, K. Integration of addiction and psychiatric services. In: Minkoff, K., and Pollack, D., eds. Managed Mental Health Care in the Public Sector: A Survival Manual. The Netherlands: Harwood Academic Publishers, 1997, pp. 233–246.
Minkoff, K. Dual Diagnosis: An Integrated Model for the Treatment of People With Co-Occurring Psychiatric and Substance Disorders in Managed Care Systems. Presentation at Building the Bridge: The Integration of Mental Health and Substance Abuse Services, Baltimore, August 5–7, 2002.
Moggi F, Ouimette P.C, Finney J.W, Moos R.H. Effectiveness of treatment for substance abuse and dependence for dual diagnosis patients: A model of treatment factors associated with one-year outcomes. Journal of Studies on Alcohol. 1999;60(6):856-866. [pmid: 10606499].
Mok D, Matthews L, Mendoza J. Changing American ethnic minority families: Highlights on Asian American African American and Hispanic/Latino Families. The Family Psychologist. 2003;19(3):4-9.
Moore D, Li L. Prevalence and risk factors of illicit drug use by people with disabilities. American Journal on Addictions. 1998;7(2):93-102. [pmid: 9598213].
Moos R, Schaefer J, Andrassy J, Moos B. Outpatient mental health care self-help groups and patients' one-year treatment outcomes. Journal of Clinical Psychology. 2001;57:273-287. [pmid: 11241359].
Moos R.H, Finney J.W, Ouimette P.C, Suchinsky R.T. A comparative evaluation of substance abuse treatment: I. Treatment orientation amount of care and 1-year outcomes. Alcoholism, Clinical and Experimental Research. 1999;23(3):529-536.
Moos R.H, Moos B.S. Long-term influence of duration and intensity of treatment on previously untreated individuals with alcohol use disorders. Addiction. 2003;98:325-337. [pmid: 12603232].
Morral, A.R.; Iguchi, M.Y.; and Belding, M.A. Reducing drug use by encouraging alternative behaviors. In: Higgins, S.T., and Silverman, K., eds. Motivating Behavior Change Among Illicit-Drug Abusers: Research on Contingency Management Interventions. Washington, DC: American Psychological Association, 1999, pp. 203–220.
Mulvey K.P, Hubbard S, Hayashi S. A national study of the substance abuse treatment workforce. Journal of Substance Abuse Treatment. 2003;24:51-57. [pmid: 12646330].
Mumola, C.J. Substance abuse and treatment, State and Federal prisoners, 1997. Bureau of Justice Statistics Special Report. Washington, DC: Office of Justice Programs, January 1999.www.ojp.usdoj.gov/bjs/abstract/satsfp97.htm[accessed February 11, 2004].
Mumola, C.J. Incarcerated parents and their children. Bureau of Justice Statistics Special Report. Washington, DC: Office of Justice Programs, August 2000.www.ojp.usdoj.gov/bjs/abstract/iptc.htm[accessed February 11, 2004].
Narcotics Anonymous. In Cooperation With Therapeutic Communities Worldwide. Presentation to the World Federation of Therapeutic Communities Conference, Cartagena, Colombia, February 1998. www.na.org/prespapers/in-cooperation.htm[accessed April 15, 2004].
Nardi D. Addiction recovery for low-income pregnant and parenting women: A process of becoming. Archives of Psychiatric Nursing. 1998;12(2):81-89. [pmid: 9573635].
National Alliance for Hispanic Health. Quality Health Services for Hispanics: The Cultural Competency Component. DHHS Publication No. 99–21. Washington, DC: U.S. Department of Health and Human Services, 2000.
National Clearinghouse on Child Abuse and Neglect Information. Substance Abuse and Child Maltreatment. Washington, DC: U.S. Department of Health and Human Services, 2003.www.nccanch.acf.hhs.gov/pubs/factsheets/subabuse_childmal.cfm[accessed May 25, 2006].
National Institute of Justice. 1996–1997 Update: HIV/AIDS, STDs, and TB in Correctional Facilities. Washington, DC: U.S. Department of Justice, July 1999.http://www.ncjrs.gov/pdffiles1/176344.pdf[accessed February 11, 2004].
National Institute on Alcohol Abuse and Alcoholism. Alcohol use among special populations (special issue). Alcohol Health & Research World 22(4), 1998.
National Institute on Drug Abuse (NIDA). Assessing Drug Abuse Among Adolescents and Adults: Standardized Instruments. The Clinical Report Series. NIH Publication No. 94–3757. Rockville, MD: NIDA, 1994.
National Institute on Drug Abuse (NIDA). Principles of Drug Addiction Treatment: A Research-Based Guide. NIH Publication No. 99–4180. Rockville, MD: NIDA, 1999, reprinted 2000.
National Institute on Drug Abuse (NIDA). Therapeutic community. NIDA Research Report Series. NIH Publication No. 02–4877. Rockville, MD: NIDA, 2002.
Naumann P, Langford D, Torres S, Campbell J, Glass N. Women battering in primary care practice. Family Practice. 1999;16(4):343-352. [pmid: 10493703].
Nebelkopf, E.; Philips, M.; and Native American Health Center Staff. Morning star rising: Healing in Native American communities (special issue). Journal of Psychoactive Drugs 35(1), 2003.
Nowinski, J.; Baker, S.; and Carroll, K.M. Twelve Step Facilitation Therapy Manual: A Clinical Research Guide for Therapists Treating Individuals With Alcohol Abuse and Dependence. NIAAA Project MATCH Monograph Series, Volume 1. DHHS Publication No. (ADM) 92–1893. Bethesda, MD: National Institute on Alcohol Abuse and Alcoholism, 1992, reprinted 1994 and 1999.
Obert J.L, McCann M.J, Marinelli-Casey P, Weiner A, Minsky S, Brethen P, Rawson R. The matrix model of outpatient stimulant abuse treatment: History and description. Journal of Psychoactive Drugs. 2000;32(2):157-164. [pmid: 10908003].
O'Connor P.G, Oliveto A.H, Shi J.M, Triffleman E.G, Carroll K.M, Kosten T.R, Rounsaville B.J, Pakes J.A, Schottenfeld R.S. A randomized trial of buprenorphine maintenance for heroin dependence in a primary care clinic for substance users versus a methadone clinic. American Journal of Medicine. 1998;105:100-105. [pmid: 9727815].
O'Farrell T.J, Choquette K.A, Cutter H.S.G. Couples relapse prevention sessions after behavioral marital therapy for male alcoholics: Outcomes during the three years after starting treatment. Journal of Studies on Alcohol. 1998;59(4):357-370. [pmid: 9647418].
O'Farrell T.J, Fals-Stewart W. Family-involved alcoholism treatment: An update. Recent Developments in Alcoholism. 2001;15:329-356. [pmid: 11449752].
O'Farrell T.J, Fals-Stewart W. Behavioral couples therapy for alcoholism and drug abuse. Journal of Substance Abuse Treatment. 2002;18:51-54. [pmid: 10636606].
O'Farrell T.J, Fals-Stewart W.A. Alcohol abuse. Journal of Marital and Family Therapy. 2003;29(1):121-146. [pmid: 12616803].
Office of Applied Studies. Summary of Findings From the 2000 National Household Survey on Drug Abuse. NHSDA Series H–13. DHHS Publication No. (SMA) 01–3549. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001.http://oas.samhsa.gov/NHSDA/2kNHSDA/2kNHSDA.htm[accessed February 11, 2004].
Office of Applied Studies. Treatment Episode Data Set (TEDS): 1992–2000, National Admissions to Substance Abuse Treatment Services. DASIS Series: S-17, DHHS Publication No. (SMA) 02–3727. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2002.wwwdasis.samhsa.gov/teds00/TEDS_2k_index.htm[accessed February 11, 2004].
Office of Applied Studies. The DASIS Report: Admissions of Persons With Co-Occurring Disorders, 2000. Rockville, MD: Substance Abuse and Mental Health Services Administration, April 2003a.http://www.oas.samhsa.gov/2k3/dualTX/dualTX.htm[accessed February 11, 2004].
Office of Applied Studies. The DASIS Report: Characteristics of Homeless Admissions to Substance Abuse Treatment, 2000. Rockville, MD: Substance Abuse and Mental Health Services Administration, August 8, 2003b.http://www.oas.samhsa.gov/2k3/homelessTX/homelessTX.htm[accessed February 11, 2004].
Ogunwole, S.U. The American Indian and Alaska Native population: 2000. Census 2000 Brief. C2KBR/01–15. Washington, DC: U.S. Census Bureau, 2002.
O'Malley S.S, Jaffe A.J, Chang G, Schottenfeld R.S, Meyer R.E, Rounsaville B. Naltrexone and coping skills therapy for alcohol dependence: A controlled study. Archives of General Psychiatry. 1992;49(11):881-887. [pmid: 1444726].
Osgood, N.J.; Wood, H.E.; and Parham, I.A., eds. Alcoholism and Aging: An Annotated Bibliography and Review. Westport, CT: Greenwood, 1995.
Osher F.C, Kofoed L.L. Treatment of patients with psychiatric and psychoactive substance abuse disorders. Hospital and Community Psychiatry. 1989;40(10):1025-1030. [pmid: 2807202].
Oslin D.W, Pettinati H, Volpicelli J.R. Older age predicts better adherence and drinking outcomes. American Journal of Geriatric Psychiatry. 2002;10:740-747. [pmid: 12427583].
Ouimette P.C, Kimerling R, Shaw J, Moos R.H. Physical and sexual abuse among women and men with substance use disorders. Alcoholism Treatment Quarterly. 2000;18(3):7-17.
Owen, P. Minnesota model: Description of a counseling approach. In: Carroll, K.M., ed. Approaches to Drug Abuse Counseling. NIH Publication No. 00–4151. Rockville, MD: National Institute on Drug Abuse, 2000, pp. 117–125.
Paluska S.A, Schwenk T.L. Physical activity and mental health: Current concepts. Sports Medicine. 2000;29(3):167-180. [pmid: 10739267].
Perry, M.J., and Mackun, P.J. Population change and distribution: 1990 to 2000. Census 2000 Brief. C2KBR/01-2. Washington, DC: U.S. Census Bureau, 2001.
Peters R.H, Greenbaun P.E, Steinberg M.L, Carter C.R, Ortiz M.M, Fry Fry, Valle S.K. Effectiveness of screening instruments in detecting substance use disorders among prisoners. Journal of Substance Abuse Treatment. 2000;18:349-358. [pmid: 10812308].
Petrakis, I.L.; Gonzalez, G.; Rosenheck, R.; and Krystal, J.H. Comorbidity of Alcoholism and Psychiatric Disorders: An Overview. Bethesda, MD: National Institute on Alcohol Abuse and Alcoholism, November 2002.http://pubs.niaaa.nih.gov/publications/arh26-2/81-89.htm[accessed February 11, 2004].
Petry N.M. A comprehensive guide to the application of contingency management procedures in standard clinic settings. Drug and Alcohol Dependence. 2000;58:9-25. [pmid: 10669051].
Physicians' Desk Reference (PDR), 53d Edition. Montvale, NJ: Medical Economics, 2003.
Pickens R.W, Battjes R, Svikis D.S, Gupman A.E. Substance use risk factors for HIV infection. Psychiatric Clinics of North America. 1993;16:119-125. [pmid: 8456038].
Preston, K.L.; Silverman, K.; and Cone, E.J. Monitoring cocaine use during contingency management interventions. In: Higgins, S.T., and Silverman, K., eds. Motivating Behavior Change Among Illicit Drug Abusers. Washington, DC: American Psychological Association, 1999, pp. 283–308.
Prochaska, J.O., and DiClemente, C.C. The Transtheoretical Approach: Crossing Traditional Boundaries of Therapy. Homewood, IL: Dow Jones and Irwin, 1984.
Prochaska, J.O., and DiClemente, C.C. Toward a comprehensive model of change. In: Miller, W.R., and Heather, N., eds. Treating Addictive Behaviors: Processes of Change. New York: Plenum Press, 1986, pp. 3–27.
Prochaska, J.O., and DiClemente, C.C. Stages of change in the modification of problem behavior. In: Hersen, M.; Eisler, R.; and Miller, P.M., eds. Progress in Behavior Modification. Sycamore, IL: Sycamore Publishing, 1992.
Prochaska, J.O.; Norcross, J.C.; and DiClemente, C.C. Changing for Good. New York: William Morrow, 1994.
Project MATCH Research Group. Matching alcoholism treatments to client heterogeneity: Project MATCH posttreatment drinking outcomes. Journal of Studies on Alcohol. 1997;58:7-29. [pmid: 8979210].
Project MATCH Research Group. Matching alcoholism treatments to client heterogeneity: Project MATCH three-year drinking outcomes. Alcoholism, Clinical and Experimental Research. 1998;22:1300-1311.
Ramirez, R.R., and de la Cruz, G.P. The Hispanic population in the United States: March 2002. Current Population Reports, P20–545. Washington, DC: U.S. Census Bureau, 2003.
Rawson, R.A. Welcome to the ISAP news. ISAP News 1(1):1, 2003.www.uclaisap.org/newsletter/documents/May-2003-ISAP-News.pdf[accessed February 11, 2004].
Rawson R.A, Huber A, Brethen P, Obert J, Gulati V, Shoptaw S, Ling W. Status of methamphetamine users 2–5 years after outpatient treatment. Journal of Addictive Diseases. 2002;21:107-119. [pmid: 11831496].
Rawson, R.A.; Obert, J.L.; McCann, M.J.; and Mann, A.J. Cocaine treatment outcome: Cocaine use following inpatient, outpatient, and no treatment. In: Harris, L.S., ed. Problems of Drug Dependence, 1985: Proceedings of the 47th Annual Scientific Meeting, the Committee on Problems of Drug Dependence, Inc. NIDA Research Monograph 67. Rockville, MD: National Institute on Drug Abuse, 1986, pp. 271–277.
Reeves, T., and Bennett, C. The Asian and Pacific Islander population in the United States: March 2002. Current Population Reports, P20–540. Washington, DC: U.S. Census Bureau, 2003.
Reoux J.P, Miller K. Routine hospital alcohol detoxification practice compared to symptom triggered management with an objective withdrawal scale (CIWA-Ar). American Journal on Addictions. 2000;9(2):135-144. [pmid: 10934575].
Richard A.J, Montoya I.D, Nelson R, Spence R.T. Effectiveness of adjunct therapies in crack cocaine treatment. Journal of Substance Abuse Treatment. 1995;12(6):401-413. [pmid: 8749724].
Richmond R, Zwar N. Review of bupropion for smoking cessation. Drug and Alcohol Review. 2003;22:203-220. [pmid: 12850907].
Ries R.K, Russo J, Wingerson D, Snowden M, Comtois K.A, Srebnik D, Roy-Byrne P. Shorter hospital stays and more rapid improvement among patients with schizophrenia substance disorders. Psychiatric Services. 2000;51:210-215. [pmid: 10655005].
Ritsher J.B, Moos R.H, Finney J.W. Relationship of treatment orientation and continuing care to remission among substance abuse patients. Psychiatric Services. 2002;53(5):595-601. [pmid: 11986510].
Robertson, E.B.; Sloboda, Z.; Boyd, G.M.; Beatty, L.; and Kozel, N.J. Rural Substance Abuse: State of Knowledge and Issues. NIDA Research Monograph 168. NIH Publication No. 97–4177. Rockville, MD: National Institute on Drug Abuse, 1997.
Rosenheck R, Harkness L, Johnson B. Intensive community-focused treatment of veterans with dual diagnoses. American Journal of Psychiatry. 1998;155(10):1429-1433. [pmid: 9766776].
Rounsaville, B.J.; Tims, F.M.; Horton, A.M.; and Sowder, B.J., eds. Diagnostic Source Book on Drug Abuse Research and Treatment. DHHS Publication No. (ADM) 93–3508. Rockville, MD: National Institute on Drug Abuse, 1993.
Rowe C.L, Liddle H.A. Substance abuse. Journal of Marital and Family Therapy. 2003;29:97-120. [pmid: 12616802].
Rubin A, Stout R.L, Longabaugh R. Gender differences in relapse situations. Addiction. 1996;91(Suppl):S111-S120. [pmid: 8997785].
Sampl, S., and Kadden, R. Motivational Enhancement Therapy and Cognitive-Behavioral Therapy for Adolescent Cannabis Users: 5 Sessions. Cannabis Youth Treatment Series, Volume 1. DHHS Publication No. (SMA) 01–3486. Rockville, MD: Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, 2001.
Schmidley, D. The foreign-born population in the United States: March 2002. Current Population Reports, P20–539. Washington, DC: U.S. Census Bureau, 2003.
Schmitz, J.M.; Henningfield, J.E.; and Jarvik, M.E. Pharmacologic therapies for nicotine dependence. In: Graham, A.W., Schultz, T.K., and Wilford, B.B., eds. Principles of Addiction Medicine, Second Edition. Chevy Chase, MD: American Society of Addiction Medicine, 1998, pp. 571–582.
Schmitz J.M, Oswald L.M, Jacks S.D, Rustin T, Rhoades H.M, Grabowski J. Relapse prevention treatment for cocaine dependence: Group versus individual format. Addictive Behaviors. 1997;22(3):405-418. [pmid: 9183510].
Schneider R, Mittelmeier C, Gadish D. Day versus inpatient treatment for cocaine dependence: An experimental comparison. Journal of Mental Health Administration. 1996;23(2):234-245. [pmid: 10172622].
Schottenfeld, R.S., and Pantalon, M.V. Assessment of the patient. In: Galanter, M., and Kleber, H.D., eds. The American Psychiatric Press Textbook of Substance Abuse Treatment, Second Edition. Washington, DC: American Psychiatric Press, 1999, pp. 109–119.
Schuckit, M.S. Goals of treatment. In: Galanter, M., and Kleber, H.D., eds. The American Psychiatric Press Textbook of Substance Abuse Treatment. Washington, DC: American Psychiatric Press, 1994, pp. 3–10.
Schumacher J.E, Milby J.B, Caldwell E, Raczynski J, Engle M, Michael M, Carr J. Treatment outcome as a function of treatment attendance with homeless persons abusing cocaine. Journal of Addictive Diseases. 1995;14(4):73-85. [pmid: 8929934].
Schwartz M, Baker G, Mulvey K.P, Plough A. Improving publicly funded substance abuse treatment: The value of case management. American Journal of Public Health. 1997;87:1659-1664. [pmid: 9357349].
Scott J, Gilvarry E, Farrell M. Managing anxiety and depression in alcohol drug dependence. Addictive Behaviors. 1998;23(6):919-931. [pmid: 9801726].
Seidner A.L, Burling T.A, Gaither D.E, Thomas R.G. Substance-dependent inpatients who accept smoking treatment. Journal of Substance Abuse. 1996;8(1):33-44. [pmid: 8743767].
Sheehan, D.V.; Lecrubier, Y.; Harnet-Sheehan, K.; Amorim, P.; Janavs, J.; Weiller, E.; Hergueta, T.; Baker, R.; and Dunbar, G. The Mini International Neuropsychiatric Interview (M.I.N.I.): The development and validation of a structured diagnostic psychiatric interview. Journal of Clinical Psychiatry (Suppl. 20):22–33, 1998.
Shoptaw S, Frosch D, Rawson R.A, Ling W. Cocaine abuse counseling as HIV prevention. AIDS Education and Prevention. 1997;9(3):15-24. [pmid: 9083596].
Shoptaw, S.; Reback, C.J.; Freese, T.E.; and Rawson, R.A. Friends Health Center: Behavioral Interventions for Methamphetamine Abusing Gay and Bisexual Men, A Treatment Manual Combining Relapse Prevention and HIV Risk-Reduction Interventions. Los Angeles: Friends Research Institute, Inc., 1998.
Shoptaw S, Rotheram-Fuller E, Yang X, Frosch D, Nahom D, Jarvik M.E, Rawson R.A, Ling W. Smoking cessation in methadone maintenance. Addiction. 2002;97:1317-1328. [pmid: 12359036].
Siegal H.A, Fisher J.A, Rapp R.C, Kelliher C.W, Wagner J.H, O'Brien W.F, Cole P.A. Enhancing substance abuse treatment with case management: Its impact on employment. Journal of Substance Abuse Treatment. 1996;13(2):93-98. [pmid: 8880666].
Siegal H.A, Li L, Rapp R.C. Case management as a therapeutic enhancement: Impact on post-treatment criminality. Journal of Addictive Diseases. 2002;21:37-46. [pmid: 12296500].
Simpson T.L, Miller W.R. Concomitance between childhood sexual and physical abuse and substance use problems: A review. Clinical Psychological Review. 2002;22(1):27-77.
Sloan K.L, Rowe G. Substance abuse and psychiatric illness: Treatment experience. American Journal of Drug and Alcohol Abuse. 1998;24(4):589-601. [pmid: 9849770].
Spicer P, Beals J, Croy C.D, Mitchell C.M, Novins D.K, Moore L, Manson S.M. the American Indian Service Utilization, Psychiatric Epidemiology, Risk and Protective Factors Project Team. The prevalence of DSM-III-R alcohol dependence in two American Indian populations. Alcoholism, Clinical and Experimental Research. 2003;27(11):1785-1797.
Stanton M.D, Shadish W.R. Outcome, attrition, and family—Couples treatment for drug abuse: A meta-analysis and review of the controlled, comparative studies. Psychological Bulletin. 1997;122(2):170-191. [pmid: 9283299].
Stasiewicz P.R, Stalker R. A comparison of three “interventions” on pretreatment dropout rates in an outpatient substance abuse clinic. Addictive Behaviors. 1999;24(4):579-582. [pmid: 10466854].
Stewart, E.C., and Bennett, M.J. American Cultural Patterns: A Cross-Cultural Perspective, Second Edition. Yarmouth, ME: Intercultural Press, 1991.
Substance Abuse and Mental Health Services Administration (SAMHSA). Report to Congress on the Prevention and Treatment of Co-Occurring Substance Abuse Disorders and Mental Disorders. Rockville, MD: SAMHSA, 2002.
Substance Abuse and Mental Health Services Administration (SAMHSA). Strategies for Developing Treatment Programs for People With Co-Occurring Substance Abuse and Mental Disorders. SAMHSA Publication No. 3782. Rockville, MD: SAMHSA, 2003.
Sue, D.W., and Sue, D. Counseling the Culturally Different: Theory and Practice, Third Edition. New York: John Wiley and Sons, 1999.
Sullivan J.T, Sykora K, Schneiderman J, Naranjo C.A, Sellers E.M. Assessment of alcohol withdrawal: The revised Clinical Institute Withdrawal Instrument for Alcohol Scale (CIWA-Ar). British Journal of the Addictions. 1989;84:1353-1357.
Szapocznik J, Kurtines W.M, Foote F.H, Perez-Vidal A, Hervis O. Conjoint versus one-person family therapy: Some evidence for the effectiveness of conducting family therapy through one person. Journal of Consulting and Clinical Psychology. 1983;51:881-889.
Szapocznik J, Kurtines W.M, Foote F.H, Perez-Vidal A, Hervis O. Conjoint versus one-person family therapy: Further evidence for the effectiveness of conducting family therapy through one person with drug-abusing adolescents. Journal of Consulting and Clinical Psychology. 1986;54:395-397. [pmid: 3722570].
Szapocznik J, Williams R.A. Brief strategic family therapy: Twenty-five years of interplay among theory, research and practice in adolescent behavior problems and drug abuse. Clinical Child and Family Psychology Review. 2000;3(2):117-134. [pmid: 11227062].
Tempesta E, Janiri L, Bignamini A, Chabac S, Potgieter A. Acamprosate and relapse prevention in the treatment of alcohol dependence: A placebo-controlled study. Alcohol and Alcoholism. 2000;35(2):202-209. [pmid: 10787398].
Tolman R.M. The development of a measure of psychological maltreatment of women by their male partners. Violence and Victims. 1989;4:159-177. [pmid: 2487132].
Tonigan J.S. Project MATCH treatment participation and outcome by self-reported ethnicity. Alcoholism, Clinical and Experimental Research. 2003;27(8):1340-1344.
Tonigan J.S, Miller W.R, Schermer C. Atheists agnostics and Alcoholics Anonymous. Journal of Studies on Alcohol. 2002;63:534-541. [pmid: 12380849].
Tracy E.M, Whittaker J.K. The social network map: Assessing social support in clinical practice. Families in Society: The Journal of Contemporary Human Services. 1990;71:461-470.
Turner R.J, Gil A.G. Psychiatric substance use disorders in South Florida: Racial/ethnic and gender contrasts in a young adult cohort. Archives of General Psychiatry. 2002;59(1):43-50. [pmid: 11779281].
Tuten M, Jones H.E. A partner's drug-using status impacts women's drug treatment Outcome. Drug and Alcohol Dependence. 2003;70(3):327-330. [pmid: 12757970].
Urban Institute; Burt, M.R.; Aron, L.Y.; Douglas, T.; Valente, J.; Lee, E.; and Iwen, B. Homelessness: Programs and the People They Serve—Findings of the National Survey of Homeless Assistance Providers and Clients, Technical Report. Washington, DC: Interagency Council on the Homeless, 1999. www.huduser.org/publications/homeless/homeless_tech.html[accessed February 11, 2004].
U.S. Census Bureau. Asian Pacific American Heritage Month: May 2003. Facts for Features. Washington, DC: U.S. Census Bureau, April 17, 2003.www.census.gov/Press-Release/www/2003/cb03-ff05.html[accessed February 11, 2004].
U.S. Department of Health and Human Services. Mental Health: A Report of the Surgeon General. Rockville, MD: Center for Mental Health Services, Substance Abuse and Mental Health Services Administration, 1999.www.mentalhealth.org/features/surgeongeneralreport/home.asp[accessed February 11, 2004].
U.S. Department of Health and Human Services. Mental Health: Culture, Race, and Ethnicity—A Supplement to Mental Health: A Report of the Surgeon General. Rockville, MD: Center for Mental Health Services, Substance Abuse and Mental Health Services Administration, 2001.www.mentalhealth.org/cre/default.asp[accessed February 11, 2004].
U.S. Government Office of Technology Assessment. Technologies for Understanding and Preventing Substance Abuse and Addiction. Washington, DC: U.S. Government Printing Office, 1994.
U.S. House Committee on the Judiciary, Subcommittee on Crime. Testimony of Bruce C. Fry, J.D., M.P.P., Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, U.S. Department of Health and Human Services. 104th Cong., 2d sess., October 2, 2000.www.house.gov/judiciary/fry1002.htm[accessed February 11, 2004].
Vaillant, G.E. The Natural History of Alcoholism. Cambridge, MA: Harvard University Press, 1983.
Veach L.J, Remley T.P Jr., Kippers S.M, Sorg J.D. Retention predictors related to intensive outpatient programs for substance use disorders. American Journal of Drug and Alcohol Abuse. 2000;26(3):417-428. [pmid: 10976666].
Vega, W.A.; Gil, A.G.; and Wagner E. Cultural adjustment and Hispanic adolescents. In: Vega, W.A., and Gil, A.G., eds. Drug Use and Ethnicity in Early Adolescence. New York: Plenum, 1998, pp. 125–148.
Vega W.A, Gil A.G, Zimmerman R.S. Patterns of drug use among Cuban-American African-American and white non-Hispanic boys. American Journal of Public Health. 1993;83(2):257-259. [pmid: 8427335].
Volpicelli J.R, Alterman A.I, Hayashida M, O'Brien C.P. Naltrexone in the treatment of alcohol dependence. Archives of General Psychiatry. 1992;49:876-880. [pmid: 1345133].
Volpicelli J.R, Markman I, Monterosso J, Filing J, O'Brien C.P. Psychosocially enhanced treatment for cocaine-dependent mothers: Evidence of efficacy. Journal of Substance Abuse Treatment. 2000;18(1):41-49. [pmid: 10636605].
Washton, A.M. Evolution of intensive outpatient treatment (IOP) as a “legitimate” treatment modality. Journal of Addictive Diseases 16(2):xxi–xxvii, 1997.
Washton, A.M. A psychotherapeutic and skills-training approach to the treatment of addiction. In: Carroll, K.M., ed. Approaches to Drug Abuse Counseling. NIH Publication No. 00–4151. Rockville, MD: National Institute on Drug Abuse, 2000, pp. 139–148.
Watkins K.E, Burnam A, Kung F.Y, Paddock S. A national survey of care for persons with co-occurring mental and substance use disorders. Psychiatric Services. 2001;52(8):1062-1068. [pmid: 11474052].
Webb, C.; Scudder, M.; Kaminer, Y.; and Kadden, R. The Motivational Enhancement Therapy and Cognitive-Behavioral Therapy Supplement: 7 Sessions of Cognitive-Behavioral Therapy for Adolescent Cannabis Users. Cannabis Youth Treatment Series, Volume 2. DHHS Publication No. (SMA) 02–3659. Rockville, MD: Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration, 2002.
Weinberg N.Z, Rahdert E, Colliver J.D, Glantz M.D. Adolescent substance abuse: A review of the past 10 years. Journal of the American Academy of Child and Adolescent Psychiatry. 1998;37:252-261. [pmid: 9519629].
Weinstein S.P, Gottheil E, Sterling R.C. Randomized comparison of intensive outpatient vs. individual therapy for cocaine abusers. Journal of Addictive Diseases. 1997;16(2):41-56. [pmid: 9083824].
Weiss R.D, Griffin M.L, Greenfield S.F, Najavits L.M, Wyner D, Soto J.A, Hennen J.A. Group therapy for patients with bipolar disorder and substance dependence: Results of a pilot study. Journal of Clinical Psychiatry. 2000;61(5):361-367. [pmid: 10847311].
Wells K, Klap R, Koike A, Sherbourne C. Ethnic disparities in unmet need for alcoholism drug abuse and mental health care. American Journal of Psychiatry. 2001;158:2027-2032. [pmid: 11729020].
White J.M, Winn K.I, Young W. Predictors of attrition from an outpatient chemical dependency program. Substance Abuse. 1998;19(2):49-59. [pmid: 12511806].
White, W.L. Slaying the Dragon: The History of Addiction Treatment and Recovery in America. Bloomington, IL: Chestnut Health Systems, 1998.
Whiteside-Mansell L. The development and evaluation of an alcohol and drug prevention and treatment program for women and children: The AR-CARES Program. Journal of Substance Abuse Treatment. 1999;16:265-275. [pmid: 10194744].
Williams, R., and Gorski, T.T. Relapse Prevention Counseling for African Americans: A Culturally Specific Model. Independence, MO: Herald, 1997.
Williams, R., and Gorski, T.T. Relapse Prevention Workbook for African Americans: Hope and Healing for the Black Substance Abuser. Independence, MO: Herald, 1999.
Williams R.J, Chang S.Y. Addiction Centre Adolescent Research Group. A comprehensive and comparative review of adolescent substance abuse treatment outcome. Clinical Psychology: Science and Practice. 2000;7:138-166.
Willoughby F.W, Edens J.F. Construct validity and predictive utility of the stages of change scale for alcoholics. Journal of Substance Abuse. 1996;8:275-291. [pmid: 8934434].
Winters F, Fals-Stewart W, O'Farrell T.J, Birchler G.R, Kelley M.L. Behavioral couple therapy for female substance-abusing patients: Effects on substance abuse and relationship adjustment. Journal of Consulting and Clinical Psychology. 2002;70:344-355. [pmid: 11952192].
Winzelberg A, Humphreys K. Should patients' religiosity influence clinicians' referral to 12-step self-help groups? Evidence from a study of 3,018 male substance abuse patients. Journal of Consulting Psychology. 1999;67:790-794.
Wiseman E.J, Henderson K.L, Briggs M.J. Individualized treatment for outpatients withdrawing from alcohol. Journal of Clinical Psychiatry. 1998;59(6):289-293. [pmid: 9671340].
Woody G.E, Donnell D, Seage G.R, Metzger D, Marmor M, Koblin B.A, Buchbinder S, Gross M, Stone B, Judson F.N. Non-injection substance use correlates with risky sex among men having sex with men: Data from HIVNET. Drug and Alcohol Dependence. 1999;53(3):197-205. [pmid: 10080045].
World Health Organization (WHO). International Classification of Diseases, 10th Edition (ICD-10) Classification of Mental and Behavioral Disorders: Clinical Descriptions and Diagnostic Guidelines. Geneva, Switzerland: WHO, 1992.
World Health Organization (WHO). Composite International Diagnostic Interview (CIDI). Core Version 2.1. Geneva, Switzerland: WHO, 1997.
Zerger, S. Substance Abuse Treatment: What Works for Homeless People? A Review of the Literature. Nashville, TN: National Health Care for the Homeless Council, 2002.
Ziedonis, D.M., and D'Avanzo, K. Schizophrenia and substance abuse. In: Kranzler, H.R., and Rounsaville, B.J., eds. Dual Diagnosis and Treatment. New York: Marcel Dekker, 1998, pp. 427–465.
Zilberman M.L, Tavares H, Blume S.B, el-Guebaly N. Substance use disorders: Sex differences and psychiatric comorbidities. Canadian Journal of Psychiatry. 2003;48(1):5-13.
Zullino D.F, Besson J, Favrat B, Krenz S, Zimmerman G, Schnyder C, Borgeat F. Acceptance of an intended smoking ban in an alcohol dependence clinic. European Psychiatry. 2003;18(5):255-257. [pmid: 12927327].