# Foreword

The Treatment Improvement Protocol (TIP) series supports the Substance Abuse and Mental Health Services Administration's mission of building resilience and facilitating recovery for people with or at risk for mental or substance use disorders by providing best-practices guidance to clinicians, program administrators, and payers to improve the quality and effectiveness of service delivery and thereby promote recovery. TIPs are the result of careful consideration of all relevant clinical and health services research findings, demonstration experience, and implementation requirements. A panel of non-Federal clinical researchers, clinicians, program administrators, and client advocates debates and discusses its particular areas of expertise until it reaches a consensus on best practices. This panel's work is then reviewed and critiqued by field reviewers.

The talent, dedication, and hard work that TIPs' panelists and reviewers bring to this highly participatory process have helped bridge the gap between the promise of research and the needs of practicing clinicians and administrators who serve, in the most current and effective ways, people who abuse substances. We are grateful to all who have joined with us to contribute to advances in the substance abuse treatment field.

- Charles G. Curie, M.A., A.C.S.W.
- Administrator
- Substance Abuse and Mental Health Services Administration

- H. Westley Clark, M.D., J.D., M.P.H., CAS, FASAM
- Director
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration