# Consensus Panel

This TIP is a consensus-based document, developed by the experts listed below. Although all panelists made significant contributions in the development of the TIP as a whole, some panelists took on the additional responsibility as writers for upfront development of particular chapters. Those chapters are listed after their names.

## Chair

- Robert F. Forman, Ph.D.
- Clinical Scientist
- Medical Affairs
- Alkermes, Inc.
- Cambridge, Massachusetts
- Formerly
- Senior Investigator
- Treatment Research Institute
- Assistant Professor of Psychology in Psychiatry
- School of Medicine
- University of Pennsylvania
- Philadelphia, Pennsylvania
- Writer, chapters 1 and 2

## Co-Chair

- Paul D. Nagy, M.S., LCAS, LPC, CCS
- Program Director
- Duke Addictions Program
- Clinical Associate
- Department of Psychiatry and Behavioral Sciences
- Duke University Medical Center
- Durham, North Carolina
- Writer, chapters 1 and 5

## Consensus Panelists

- Fred Andes, D.S.W., M.P.A., LCSW
- Assistant Professor of Sociology
- New Jersey City University
- Jersey City, New Jersey
- Writer, chapters 5 and 6

- Margaret K. Brooks, J.D.
- Consultant
- 27 Warfield Street
- Montclair, New Jersey
- Writer, chapter 9

- Frederick T. Chappelle, M.S.S.W., LCADC, CCS
- Vice President and Financial Officer
- Chappelle Consulting and Training Services, Inc.
- Middletown, Connecticut

- Gerard J. Connors, Ph.D.
- Director
- Research Institute on Addictions
- University of Buffalo
- Buffalo, New York
- Writer, chapters 4 and 5

- Anita L. Crawford
- Chief Executive Officer
- Roxbury Comprehensive Community Health Center
- Roxbury, Massachusetts

- Chris B. Farentinos, M.D., CADC II, NCDC II
- Clinical Director
- Change Point, Inc.
- Portland, Oregon
- Writer, chapters 4, 7, 8, and 10

- Marco E. Jacome, M.A., LPC, CSADC, CEAP
- Executive Director
- Healthcare Alternative Systems, Inc.
- Chicago, Illinois
- Writer, chapter 10

- George Kolodner, M.D.
- Medical Director
- Kolmac Clinic
- Silver Spring, Maryland
- Writer, chapter 4

- Felicity L. LaBoy, Ph.D.
- Clinical Coordinator
- Dual Diagnoses Program
- Substance Abuse Services
- Bronx VA Medical Center
- Bronx, New York
- Writer, chapters 3, 4, and 9

- Janice Ogden Lipscomb, M.S., ACADC
- Director
- Mental Health and Chemical Dependency Community Based Programs
- Broadlawns Medical Center
- Des Moines, Iowa
- Writer, chapters 3 and 8

- Mary E. McCaul, Ph.D.
- Associate Professor
- Psychiatry and Behavioral Sciences
- Johns Hopkins University School of Medicine
- Baltimore, Maryland
- Writer, chapters 8 and 9

- Elizabeth A. Peyton
- Principal
- Peyton Consulting Services
- Newark, Delaware
- Writer, chapters 8 and 9

- Richard A. Rawson, Ph.D.
- Associate Director
- UCLA Integrated Substance Abuse Programs
- Los Angeles, California
- Writer, chapter 2

- Candace M. Shelton, M.S., CSAS, CADAC, CCS
- Consultant
- Tucson, Arizona
- Writer, chapter 10

## KAP Expert Panel and Federal Government Participants

- Barry S. Brown, Ph.D.
- Adjunct Professor
- University of North Carolina at Wilmington
- Carolina Beach, North Carolina

- Jacqueline Butler, M.S.W., LISW, LPCC, CCDC III, CJS
- Professor of Clinical Psychiatry
- College of Medicine
- University of Cincinnati
- Cincinnati, Ohio

- Deion Cash
- Executive Director
- Community Treatment and Correction Center, Inc.
- Canton, Ohio

- Debra A. Claymore, M.Ed.Adm.
- Owner/Chief Executive Officer
- WC Consulting, L.L.C.
- Loveland, Colorado

- Carlo C. DiClemente, Ph.D.
- Chair
- Department of Psychology
- University of Maryland Baltimore County
- Baltimore, Maryland

- Catherine E. Dube, Ed.D.
- Independent Consultant
- Brown University
- Providence, Rhode Island

- Jerry P. Flanzer, D.S.W., LCSW, CAC
- Chief, Services
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- Bethesda, Maryland

- Michael Galer, D.B.A.
- Chairman of the Graduate School of Business
- University of Phoenix—Greater Boston Campus
- Braintree, Massachusetts

- Renata J. Henry, M.Ed.
- Director
- Division of Alcoholism, Drug Abuse, and Mental Health
- Delaware Department of Health and Social Services
- New Castle, Delaware

- Joel Hochberg, M.A.
- President
- Asher & Partners
- Los Angeles, California

- Jack Hollis, Ph.D.
- Associate Director
- Center for Health Research
- Kaiser Permanente
- Portland, Oregon

- Mary Beth Johnson, M.S.W.
- Director
- Addiction Technology Transfer Center
- University of Missouri-Kansas City
- Kansas City, Missouri

- Eduardo Lopez, B.S.
- Executive Producer
- EVS Communications
- Washington, D.C.

- Holly A. Massett, Ph.D.
- Academy for Educational Development
- Washington, D.C.

- Diane Miller
- Chief
- Scientific Communications Branch
- National Institute on Alcohol Abuse and Alcoholism
- Bethesda, Maryland

- Harry B. Montoya, M.A.
- President/Chief Executive Officer
- Hands Across Cultures
- Espanola, New Mexico

- Richard K. Ries, M.D.
- Director/Professor
- Outpatient Mental Health Services Dual Disorder Programs
- Seattle, Washington

- Gloria M. Rodriguez, D.S.W.
- Research Scientist
- Division of Addiction Services
- New Jersey Department of Health and Senior Services
- Trenton, New Jersey

- Everett Rogers, Ph.D.
- Center for Communications Programs
- Johns Hopkins University
- Baltimore, Maryland

- Jean R. Slutsky, P.A., M.S.P.H.
- Senior Health Policy Analyst
- Agency for Healthcare Research and Quality
- Rockville, Maryland

- Nedra Klein Weinreich, M.S.
- President
- Weinreich Communications
- Canoga Park, California

- Clarissa Wittenberg
- Director
- Office of Communications and Public Liaison
- National Institute of Mental Health
- Bethesda, Maryland

## Consulting Members to the KAP Expert Panel

- Paul Purnell, M.A.
- Social Solutions, L.L.C.
- Potomac, Maryland

- Scott Ratzan, M.D., M.P.A., M.A.
- Academy for Educational Development
- Washington, D.C.

- Thomas W. Valente, Ph.D.
- Director, Master of Public Health Program
- Department of Preventive Medicine
- School of Medicine
- University of Southern California
- Alhambra, California

- Patricia A. Wright, Ed.D.
- Independent Consultant
- Baltimore, Maryland