# Executive Summary

This volume, Substance Abuse: Administrative Issues in Outpatient Treatment, and its companion text, Substance Abuse: Clinical Issues in Intensive Outpatient Treatment, revisit the subject matter of TIP 8, Intensive Outpatient Treatment for Alcohol and Other Drug Abuse, published in 1994 (CSAT 1994). When TIP 8 was published, one slender volume, barely more than 100 pages long, sufficed to cover intensive outpatient treatment (IOT). The same task today requires two volumes, each of which is devoted to a distinct audience (administrators and clinicians) and is longer than the single, original volume.

The primary audience for this TIP is administrators of outpatient substance abuse treatment programs. A few words about this audience are in order. Whereas TIP 8 addressed intensive outpatient treatment, the current TIP drops the word “intensive” from its title because the consensus panel hopes that this TIP will find an audience beyond administrators of IOT programs. Most of the concepts and guidelines included in this TIP apply to the administration of all substance abuse outpatient treatment (OT) programs. On those rare occasions when information applies only to IOT programs, the authors have been sure to make this clear. Although the term “administrator” is used most often to describe the audience for this book, the terms “executive” and “director” appear as well and are used interchangeably with administrator. These overlapping terms emphasize the varied roles and responsibilities that administrators assume.

## The Changing IOT Landscape

Arnold M. Washton (1997) points out that the first large expansion of IOT took place during the 1980s, when White, middle-class individuals with cocaine addiction, many of whom were business professionals, sought treatment and did not want to take time away from work or face the stigma of checking into a residential treatment facility. A second expansion of IOT was ushered in by managed care, with its focus on cost containment. Throughout the 1990s, IOT grew, becoming the dominant treatment for most individuals with substance use disorders. This growth was spurred by the expansion of IOT's population from clients with few serious risk factors to include clients who are homeless, adolescents, and those with co-occurring mental disorders, all of whom were formerly considered too difficult for IOT programs to treat successfully. The updated information and the current volume's focus on administrators are testaments not just to the proliferation of IOT programs, but also to the greater variety of services these programs now provide to a broader client population.

Along with the increased complexity of the treatment landscape come more challenges for the administrators who oversee IOT programs. When TIP 8 was written, IOT was seen primarily as a bridge between 28-day inpatient treatment and low-intensity outpatient treatment or mutual-help relapse prevention; most clients were insured privately. IOT programs proved to be adept at filling that treatment gap, and they took on more roles. Public funding sources began to refer more of their Medicaid patients to IOT programs. This development compelled IOT administrators to adapt existing programs and develop new methods to treat diverse clients.

A second force that drove the diversification of IOT programs was managed behavioral health care. Because IOT was cheaper than residential treatment and was being used successfully to treat a wider range of clients, IOT increasingly was seen as a way for managed care organizations (MCOs) to reduce costs. As a result of IOT's successes and the cost containment it made possible, today IOT is a valuable treatment modality in its own right, in addition to being an intermediate stage in the clinical continuum.

Substance Abuse: Administrative Issues in Outpatient Treatment represents the major concerns identified by the consensus panel that relate to the development, expansion, and administration of OT programs.

## Administrative and Staffing Issues

Because of this TIP's administrative focus, the authors give special attention to issues faced by directors of OT programs. A more general overview and discussion of attributes and skills required of supervisors in treatment programs can be found in the Center for Substance Abuse Treatment's forthcoming Technical Assistance Publication Competencies for Substance Abuse Treatment Clinical Supervisors (CSAT forthcoming a ).

Most clinic directors were at one time counselors, and the transition from treatment to management is not always a smooth one. The skills that served the counselor well (empathy, patience) may not be those an administrator will rely on primarily. Skills that are necessary for administrators—mentoring, teaching, accounting, evaluation, leadership—often are not acquired at the supervisory level either (Gallon 2002). Administrators face the additional problem of there being little guidance available from the existing literature. So scarce were articles on the job of program administrators that members of the consensus panel for Substance Abuse: Administrative Issues in Outpatient Treatment drew primarily on their own experiences in writing this TIP. Coupled with the lack of information on making the transition from counselor to clinic director is the problem of high turnover in the administrative ranks. The National Treatment Center Study found 31 percent annual turnover rates in IOT administration (National Treatment Center Study 1997). With nearly a third of programs experiencing some type of administrative change each year, laying out guidelines and procedures for administrators is essential.

Turnover of substance abuse treatment counselors is also a serious problem, which means that program administrators must devote resources and creativity to hiring and retaining qualified counselors. Although this TIP discusses core staffing issues (e.g., staff member roles, shared knowledge, clinical competence), it also addresses hiring and retaining high-quality staff members, staff supervision, training, and continuing education. An emphasis in this volume is on managing staff stressors and supporting the development of counselors and staff—practices that will help mitigate counselor turnover. Substance abuse treatment counselors' turnover rate is far above the national average for all careers and higher even than rates for occupations, such as teacher and nurse, that have notoriously high turnover (Johnson 2002). The National Treatment Center Study found that more than half the counselors surveyed had been working in their current programs for less than 4 years. Nearly 20 percent of all counselors had been working in their current jobs for less than a year (National Treatment Center Study 1999). With the proliferation of treatment programs, the job market for qualified and talented counselors has become more competitive. Given the expense that goes into recruiting and training, programs can ill afford to lose experienced and skilled counselors and staff members. In a time of tight budgets, programs may need to rely on inducements such as increased job satisfaction and opportunities for professional advancement, rather than pay increases, to retain qualified staff.

## IOT's Connections to Strategic Partners

When TIP 8 was written, IOT was on the cusp of its second major expansion. The authors felt the need to offer arguments for the legitimacy of IOT and devoted a chapter to explaining how IOT fits into the continuum of care. Substance Abuse: Administrative Issues in Outpatient Treatment takes as a given that IOT plays a central role in the treatment of substance use disorders. Convinced that IOT is an integral part of the treatment landscape, the authors of the current volume focus on strategies for program survival and growth. Exploring ways for programs to expand their services to treat more and different clients is a major theme that emerges from this volume. The most effective way for programs to broaden services and increase the number of clients being served is through community and health care partnerships. Nearly every chapter in this TIP addresses this issue in some way.

IOT's initial positioning as an intermediate stage between residential and outpatient treatment necessitated connections with other treatment providers. The emphasis on connections—fundamental at the inception of IOT—remains a strength of the way programs are run today. One advantage of IOT is that it allows clients to receive treatment while they stay connected with and participate in the social networks that shape their lives. Family, friends, and colleagues are present as supports but also as stressors that allow clients to gauge their progress in the real world outside treatment.

OT programs also are connected to the real world of the communities in which they are located; these connections to residents, community leaders, religious and charitable groups, and civic organizations are a source of strength and support for OT programs, and they emerge as a theme in Substance Abuse: Administrative Issues in Outpatient Treatment. Several chapters in the book discuss the benefits of community outreach as a marketing and educational tool, a way to raise the profile of programs in communities, and a way to increase awareness of substance use disorders, their signs, and treatment. This volume urges program administrators to think of community connections as a two-way street, going beyond services provided to the community to include involvement and feedback from the community. Community surveys can help direct program efforts to meet local needs. Community members can provide valuable input on matters of racial, ethnic, and cultural diversity and can be tapped to serve on the board of directors.

This theme of connection emphasizes the links between OT programs and strategic partners. Linking with hospitals, the criminal justice system, mental health service providers, mutual-help programs, and other treatment programs in the area broadens both a program's pool of potential clients and the services it can provide. Treating health management organizations as partners can benefit a program by facilitating a positive working relationship. Robust relationships with government officials, State regulators, and State and private funding agencies can play a significant role in a program's continued survival and growth. The consensus panel members note that the sheer number of service connections a program must establish and the coordination that must take place between treatment programs and strategic partners move these multiple systems beyond interaction and toward convergence, where all partners mutually support the goals of treatment.

## Program Promotion

Another theme that emerges from this volume is the variety of marketing opportunities available to programs and the importance of taking advantage of them. Making a program more available to the public and more of a presence in the community can encourage community members, funders, and officials to feel more connected to and invested in the success of the program. Observing day-to-day operations and special events such as client graduations gives people a clear picture of the work the program performs, the staff members it employs, and the clients it serves. Increasing the visibility of the program and its activities can reduce the stigma associated with substance use disorders. A program that portrays recovery in a positive light and demonstrates its effects on individuals, families, and the community may see an increase in clients and in support from State and local officials. Regular program reports sent to members of the local media, community leaders, and public and private funders can serve as both a public relations and a fundraising tool. Publicizing the successes and cost-effectiveness of a program persuades supporters that their involvement is making a difference and that the program is “a form of social investment that may deserve more attention and more funds” (Yates 1999, pp. 1–2).

Performance improvement and outcomes monitoring can serve as powerful promotional tools for OT programs, in addition to helping them meet requirements of funding and credentialing bodies. The underlying principles of performance improvement were formulated more than 50 years ago and have been influencing American business practices for a quarter century. In the 10 years since TIP 8 was released, driven by the requirements of credentialing bodies and payers, performance improvement has become increasingly important to substance abuse treatment providers.

Many States now include outcomes monitoring as a requirement for licensure and establishing permanent statewide monitoring systems. MCOs and other payers are implementing incentives and sanctions that are pegged to outcomes. And the Federal Government, through the U.S. Department of Health and Human Services and the Center for Substance Abuse Treatment, is developing performance indicators, databases, and information systems to monitor outcomes. Outcomes monitoring need not function only as a stick, driving programs to improve so that they can receive credentials or funding; it can serve also as a carrot, rewarding programs with better service delivery, more satisfied clients, and increased revenues. Program monitoring is especially important when a new service has been implemented or when the staff identifies a problem area. Data gathered from outcomes monitoring can be used to publicize the success of programs to State officials, funders, and potential clients. Enhancing program visibility in these ways can be crucial to survival. Administrators rate their program's reputation as the most important competitive advantage they have over other treatment providers, followed closely by client satisfaction (National Treatment Center Study 2002). Outcomes monitoring and performance improvement can help increase client satisfaction and thereby enhance a program's reputation, allowing it to succeed in difficult times.

## Cultural and Financial Changes That Affect OT Programs

### Cultural Changes

The term “cultural competence” has come into wide use to describe treatment that is mindful of the commonalities and differences among various racial, ethnic, and religious groups and a treatment environment that encourages understanding and exploration of difference. Despite the widespread support that cultural competence enjoys in society at large and within the treatment community, some claim that, as it is implemented in substance abuse treatment, it puts ideology before evidence-based practice and passion before common sense (Weinrach and Thomas 1998). Others who support cultural competence point out that 85 percent of counselors are White, but nearly half the client population is not White. Stated flatly, “Treatment professionals are generally not from the same ethnic and racial backgrounds as the clients they serve” (Mulvey et al. 2003, p. 56). For clinicians to treat diverse client populations responsibly, attention to culture is essential. As long as a cultural disparity persists, program administrators should prepare their counselors and other staff members to understand and address the needs of diverse clients. In addition, it will be beneficial to present pragmatic information on assessing treatment and community needs, training staff to be more culturally competent, and implementing cultural competence plans. Toward that end, Substance Abuse: Administrative Issues in Outpatient Treatment defines cultural competence and explains its significance for treatment programs. But the bulk of the cultural competence discussion focuses on how to evaluate community needs, client satisfaction, and program capability with respect to cultural competence. Coupled with examples of surveys, assessment forms, and extensive annotated lists of resources and training materials, the practical guidelines for cultural competence assessment are a first step toward the pragmatic strategies and interventions that critics of current cultural competence efforts see as lacking (Weinrach and Thomas 1998).

### Financial Changes

Financing of OT programs has changed more than any other aspect of program administration in recent years. Although changes in the funding landscape were underway in 1994 when TIP 8 was published, only in the intervening decade has the extent to which managed care dominates health care funding become clear. In 1995 less than a third of substance abuse treatment facilities had managed care contracts. Four years later, more than half the facilities had contracts (Office of Applied Studies 2001), and the growth continues. Today, more than two-thirds of Americans have their behavioral health benefits covered through an MCO (Oss and Clary 1999). Befitting the increased role of managed care in funding treatment facilities, most of the financial discussion in Substance Abuse: Administrative Issues in Outpatient Treatment is devoted to managed care. Working with MCOs for the good of clients is essential. Of programs surveyed, 54 percent reported that they had to negotiate with MCOs for initiation or continuation of treatment for at least half their clients (National Treatment Center Study 1997). Programs report that there is more intense competition for outpatient services than for any other substance abuse treatment services (National Treatment Center Study 2002). To assist program administrators in this competitive environment, this TIP also provides guidance on the financial aspects of starting a treatment program and on diversifying funding streams to stay in business and thrive.