# Consensus Panel

This TIP is a consensus-based document, developed by the experts listed below. Although all panelists made significant contributions in the development of the TIP as a whole, some panelists took on the additional responsibility as writers for upfront development of particular chapters. Those chapters are listed after their names.

## Chair

- Robert F. Forman, Ph.D.
- Clinical Scientist
- Medical Affairs
- Alkermes, Inc.
- Cambridge, Massachusetts
- Formerly
- Senior Investigator
- Treatment Research Institute and
- Assistant Professor of Psychology in Psychiatry
- School of Medicine
- University of Pennsylvania
- Philadelphia, Pennsylvania
- Writer, chapters 1, 2, 3, 5, and 6

## Co-Chair

- Paul D. Nagy, M.S., LCAS, LPC, CCS
- Program Director
- Duke Addictions Program
- Clinical Associate
- Department of Psychiatry and Behavioral Sciences
- Duke University Medical Center
- Durham, North Carolina
- Writer, chapters 1 and 2

## Consensus Panelists

- Fred Andes, D.S.W., M.P.A., LCSW
- Assistant Professor of Sociology
- New Jersey City University
- Jersey City, New Jersey

- Margaret K. Brooks, J.D.
- Consultant
- 27 Warfield Street
- Montclair, New Jersey

- Frederick T. Chappelle, M.S.S.W., LCADC, CCS
- Vice President and Financial Officer
- Chappelle Consulting and Training Services, Inc.
- Middletown, Connecticut
- Writer, chapters 3 and 4

- Gerard J. Connors, Ph.D.
- Director
- Research Institute on Addictions
- University of Buffalo
- Buffalo, New York

- Anita L. Crawford
- Chief Executive Officer
- Roxbury Comprehensive Community Health Center
- Roxbury, Massachusetts

- Chris B. Farentinos, M.D., CADC II, NCDC II
- Clinical Director
- Change Point, Inc.
- Portland, Oregon
- Writer, chapter 4

- Marco E. Jacome, M.A., LPC, CSADC, CEAP
- Executive Director
- Healthcare Alternative Systems, Inc.
- Chicago, Illinois
- Writer, chapter 4

- George Kolodner, M.D.
- Medical Director
- Kolmac Clinic
- Silver Spring, Maryland

- Felicity L. LaBoy, Ph.D.
- Clinical Coordinator
- Dual Diagnoses Program
- Substance Abuse Services
- Bronx VA Medical Center
- Bronx, New York

- Janice Ogden Lipscomb, M.S., ACADC
- Director
- Mental Health and Chemical Dependency Community Based Programs
- Broadlawns Medical Center
- Des Moines, Iowa

- Mary E. McCaul, Ph.D.
- Associate Professor
- Psychiatry and Behavioral Sciences
- Johns Hopkins University School of Medicine
- Baltimore, Maryland

- Elizabeth A. Peyton
- Principal
- Peyton Consulting Services
- Newark, Delaware

- Richard A. Rawson, Ph.D.
- Associate Director
- UCLA Integrated Substance Abuse Programs
- Los Angeles, California

- Candace M. Shelton, M.S., CSAS, CADAC, CCS
- Consultant
- Tucson, Arizona