# Chapter 3. Managing Human Resources

Outpatient treatment (OT) and intensive outpatient treatment (IOT) programs work with profoundly compromised clients. The challenge may be greatest in the public sector, where the usual needs of clients with substance use disorders are compounded by poverty, illiteracy, co-occurring mental disorders, discrimination, HIV and hepatitis C infection, and histories of abuse, homelessness, and isolation. Moreover, unlike many other health care providers, IOT programs are expected to provide this care to clients without the controls of residential care and in groups instead of individually because funds are scarce. Working in IOT programs requires a highly developed set of skills, which makes managing human resources especially important.

The consensus panel recommends that, to be effective, programs attract, train, and retain skilled staff members who are dedicated to providing competent and compassionate care. This chapter is designed to help programs meet some of the challenges that administrators face, including the following:

- A scarce supply of experienced staff. Because IOT is a relatively new level of care, few clinicians have long-term experience working in IOT programs. This shortage is particularly acute for counselors from ethnic and minority groups.
- Increasing demand in other systems for trained counselors. Programs face competition from other systems such as criminal justice and social services, which are adding counselors.
- Low pay. In some areas, counselors in treatment programs are paid less than food service and janitorial workers. In 2002, the average starting salary for counselors surveyed in the National Treatment Center Study was $28,000, the equivalent of $13.50 per hour (National Treatment Center Study 2002). In 1999, more than half of the counselors surveyed were making $30,000 or less annually. Nearly one in five counselors was making $20,000 or less (National Treatment Center Study 1999).
- Long hours and inconsistent work schedules. Clinical coverage often demands evening and weekend hours, which can result in staff members' feeling isolated from their colleagues and support services. Sometimes staff members are required to work broken day shifts, which, like evening and weekend schedules, can interfere with family life.
- Paperwork. The consensus panel estimates that up to 40 percent of providers' time is spent completing paperwork.
- Stressful demands of the treatment population. Unpredictable client behavior, high risk of crisis, and “secondary trauma” (resulting from listening to clients recount their traumatic experiences) place extra demands on staff.
- Time required to handle complex client issues. Programs address client retention, relapse, employment problems, psychosocial issues, and family problems, but they also must devote time to case management, networking with employee assistance programs (EAPs), employers, social service agencies, mental health care providers, and the criminal justice system.
- Limited community resources. In some areas, treatment is complicated further by a lack of community resources. The clinical staff is required to put extra effort into nontraditional substance abuse treatment tasks, such as providing assistance with vocational placement, housing, and transportation.

A program should employ and retain clinical staff members who are empathic, caring, and able to function in this stressful environment. It is important that clinicians be autonomous, while functioning as part of a multidisciplinary team.

This chapter covers the following key issues:

- Policy issues and guidelines
- Guidelines for staffing
- Selection of qualified and competent clinical staff
- Staff supervision
- Continuing education and training
- Motivating and retaining staff

## Policy Issues and Guidelines

Establishing formal written policies and procedures provides guidelines for staff members, ensures that they understand their roles and responsibilities, provides security and stability for them, and outlines the ethical and behavioral standards expected of them. Administrators should consider having all staff members sign copies of policies to document that they have read and understand them.

### Program Philosophy

The program philosophy should express a clear vision and mission, consistent with the daily operations of the program. The philosophy statement defines performance expectations, standards for effective and ethical treatment interventions, and the relationship between clinician and client. It also specifies standards that encourage high-quality care, professionalism, and a commitment to the well-being of clients and staff. This document should refer to the specific treatment theories and evidence-based practices used by the program. It should be reviewed and amended regularly. (For more information on developing strategic and operating plans, see chapter 2.)

### Shared Staff Attitudes and Knowledge

It is helpful when staff members have similar treatment orientations. If one program philosophy does not hold sway, clients may find themselves caught between clinicians with different approaches and conflicting treatment recommendations. Staff and management should work together to develop the program philosophy. Treatment beliefs about which staff should agree include

- Addiction is a biopsychosocial and spiritual disorder, best treated by multidisciplinary approaches; it cannot be treated effectively or exclusively by any one discipline or orientation. For some clients, this may include medication in combination with counseling and behavioral therapies.
- Recovery is possible, and together staff members can treat people with addiction successfully.
- Recovery support groups, such as mutual-help programs, are vital aspects of treatment and recovery.

### Policies and Protocols on Professional and Ethical Responsibilities

Management is obligated to ensure that all staff members, and counselors in particular, are knowledgeable about and adhere to accepted professional and ethical standards of conduct.

#### Professional code of ethics

Treatment providers come from many different professions, each of which has its own professional code of ethics. These codes are the basis for identifying and managing ethical issues, and staff should adhere to them.

Staff members also should be held accountable for maintaining professional standards and client safety. A program might wish to adopt the code of ethics used by its State board of counselors. Exhibit 3-1 lists professional standards that should be discussed with staff. A source of information is the code of ethics developed by NAADAC, The Association for Addiction Professionals, downloadable at naadac.org/documents/display.php?DocumentID=11.

Exhibit 3-1. Issues Regarding Professional Standards

A counselor should demonstrate the following:
• Familiarity with mandatory reporting requirements
• Adherence to professional standards and scope of practice
• Knowledge of the difference between a clinical relationship and that of a peer counselor or sponsor to a client
• Willingness to use clinical supervision and peer assessments to gain insights into clinical deficiencies
• Awareness of current research and trends in addiction and related fields
• Involvement in professional organizations
• Respect for clients from diverse backgrounds
• Recognition of the effect that personal bias toward other cultures and lifestyles can have on treatment
• Understanding of personal recovery and its effect on the provision of treatment
• Capacity to conduct self-evaluation
• Participation in regular continuing education
• Use of self-care strategies

#### Conflicts of interest

The policy about conflicts of interest should be clear to staff members, particularly part-time staff members who often have affiliations with other agencies. For example, a senior-level person who works part-time in the program also may run the best recovery house in the area. This staff person will benefit personally from referring clients to that facility. Clinic policy should ensure that all referrals are based on the client's need and choice—not on personal benefit of staff members. Ethical guidelines protect both the clinic and the client.

#### Guidelines to protect staff safety and health

Policies and procedures to safeguard staff safety and health should be framed according to the program's client population. For example, counselors' personal safety may be at risk with severely impaired clients. The consensus panel recommends that at least two staff members be on site whenever clients are present.

#### Standards for staff-client relationships

The program should have clearly stated ethical standards that delineate boundaries for staff-client relationships. Because staff members may see clients in the community, clear guidelines are needed about staff contact with clients outside the program, including policies on romantic relationships between staff and clients and on protecting client confidentiality. Such guidelines should address specifically the issue of staff members who participate in recovery support groups.

#### Review of complaints and incidents

Counselors sometimes work in isolation and may be susceptible to charges of misconduct. Programs should have clear policies about sexual harassment, sexual relations, and other violations of professional conduct and have a protocol for reviewing and documenting incidents and complaints. These incidents should be handled immediately.

## Guidelines for Staffing

An OT program needs a core full-time staff that is responsible for maintaining continuity of care. The program should be run by this core of clinical staff members who consider the program their primary employer. Although many programs depend on part-time employees, an OT program should not be run exclusively with part-time staff unless it serves a very small or specialized population.

### Staff Roles and Responsibilities

In large programs, some clinical services may be provided by specialists. In small programs, some staff members might need to be trained to provide comprehensive services. IOT programs that offer distinctive treatment, such as medically managed detoxification, family therapy, and recreation and leisure activities, may require physicians, physician's assistants, family therapists, or certified recreation therapists. OT program personnel fall into four categories:

1. Core clinical staff provides such direct client treatment services as assessment, counseling, case management, crisis interventions, and clinical supervision; OT-based detoxification programs also need appropriate medical staff.
2. Clinical management includes clinical supervisors with certified supervisory status and relevant clinical experience, as well as case managers.
3. Specialized services may include the multidisciplinary team psychologist, psychiatrist, social worker, vocational counselor, family therapist, and outside consultants who provide education, case management, and transition and discharge planning; medical staff provides examinations, assessments, and medication management.
4. Administrative, clerical, and support staff performs such administrative functions as program planning, quality assurance, fiscal management, logistical support, information management, contracts management, and regulatory compliance. Outreach workers are becoming increasingly important for some OT programs. Security guards also may be part of support staff.

#### Multidisciplinary teams

Staff members should be hired with an eye toward building a multidisciplinary team. The multidisciplinary team may include full-time, part-time, or consultant workers whose skills overlap. For example, nurses and social workers also may serve as addiction counselors. As the treatment field grows, less attention is being given to a person's training or discipline and more attention is being paid to the person's competence in addiction treatment and in the treatment of co-occurring disorders. The size of teams varies according to the facility, but each team should be able to address

- Medical services
- Counseling
- Case management
- Family services
- Social services
- Psychological services
- Psychiatric services
- Liaison with criminal justice, child welfare, and other agencies
- Other ancillary services

The consensus panel realizes that this type of robust staffing is possible only with adequate funding. Programs may not be able to supply all these services. Setting up linkages and a system for collaborating with other agencies is imperative.

#### Specialized services

Core staff members often are able to provide many specialized services needed in a program. Some services include

- Vocational rehabilitation
- Recreational therapy
- Art, music, and dance therapy
- Nutrition counseling
- HIV/AIDS counseling
- Spiritual counseling
- Literacy and general equivalency diploma preparation

#### Clerical and administrative staff

Clerical staff members are often the first individuals to have contact with potential clients and their families. The nature of this initial interaction can help determine whether the client successfully enters treatment. Administrative staff members are responsible for communicating information about the program to potential clients and referral sources. Outreach workers who know the community can play a crucial role in engaging clients in treatment. Security guards can be a welcoming, protective presence. These individuals are valuable team members and should receive training about substance use disorders, the nature of the program, positive client relations, and confidentiality regulations. They also must be appropriately supervised and supported.

#### Interns and trainees

Recruiting students or program alumni to be interns is a good way to train qualified staff. A program can form a partnership with the department of psychology or social work at a local university or community college. Interns and trainees can perform many clinical and nonclinical functions. These trainees may include

- Physicians and medical students who are participating in addiction medicine internships
- Undergraduate and graduate students in clinical psychology, counseling, social work, and addiction studies
- Nurses preparing for a specialty in addiction

Trainees and interns can be valuable adjuncts to the program and should be incorporated into staff planning. The consensus panel recommends that programs develop policies pertaining to the recruitment, oversight, and granting of clinical privileges to intern staff members and develop written policies and procedures for notifying clients that their care may be provided in part by interns and trainees. The qualifications of interns and trainees affect reimbursement. Some addiction treatment trainees may be qualified as counselors and be eligible for reimbursement.

### Staff in Recovery

Many programs recruit and hire counselors who are in personal recovery. According to the National Treatment Center Study, which surveyed 400 programs, 60 percent of counselors were in recovery (National Treatment Center Study 1999). Counselors and staff members in recovery bring a valuable perspective to the treatment of clients with substance use disorders. The consensus panel recommends that program staffs include both professionally trained clinicians who are in personal recovery and those who have no personal addiction experience. The balance of perspectives is valuable for programs, regardless of the treatment model. A policy about the length of time counselors must be in recovery before being hired is needed (see exhibit 3-2). For example, programs generally do not hire applicants who have less than a year in recovery, although they may hire people in early recovery for noncounseling positions. A written policy protects the program if someone challenges its hiring policy for counseling positions.

Exhibit 3-2. Laws Regarding Hiring and Employing Staff in Recovery

Two Federal laws protect certain individuals with substance use disorders from discrimination in employment: the Federal Rehabilitation Act (29 United States Code [U.S.C.] § 791 et seq. [1973]) and the Americans with Disabilities Act (ADA) (42 U.S.C. § 12101 et seq. [1992]). These laws protect individuals who have histories of substance use disorders, some people who currently abuse substances, and individuals who currently are receiving treatment. Some States also provide protection to individuals who formerly abused or currently abuse substances. Not all programs are subject to these laws.
1. The laws generally regard people with substance use disorders as individuals with disabilities but distinguish between individuals who are in recovery and those who currently abuse substances and between alcohol abuse and illegal drug abuse.
| a. Individuals in recovery. The laws protect people who abused alcohol and drugs in the past and are in recovery.
| b. Individuals who abuse alcohol. The laws provide limited protection against employment discrimination to people who currently abuse alcohol but who can perform the requisite job duties and do not pose a direct threat to the health, safety, or property of others in the workplace.
| c. Individuals who abuse illegal drugs. The laws do not protect people currently abusing illegal drugs, even if they are qualified and do not pose a direct threat to others in the workplace.
| d. Individuals in treatment. Individuals who are participating in a supervised rehabilitation program and no longer are engaged in drug or alcohol abuse are protected.
2. The laws protect only individuals who are “qualified” for employment. The ADA defines a “qualified individual with a disability as an individual . . . who, with or without reasonable accommodation, can perform the essential functions of the employment position that such individual holds or desires. [C]onsideration shall be given to the employer's judgment as to what functions of a job are essential, and if an employer has prepared a written description before advertising or interviewing applicants for the job, this description shall be considered evidence of the essential functions of the job” (42 U.S.C. § 1211(8)).
3. The laws prohibit the use of standards or other selection criteria that screen out individuals with a disability unless the standards or selection criteria are shown to be job related to the position and are consistent with business necessity (42 U.S.C. § 12112(b)).
4. The laws prohibit preemployment medical examinations or inquiries about applicants' disabilities (or the severity of disabilities) “unless such examination or inquiry is shown to be job-related and consistent with business necessity” (42 U.S.C. § 12112(d)(4)).
It is important to note that laws can differ from State to State and that Federal laws change. Providers are advised to consult their human resources department or legal counsel for the most up-to-date laws and statutes.

#### Personnel policies regarding staff misuse of alcohol or drugs

Programs should maintain a drug-free workplace. Clinics should explore the use of drug testing for employees. Drug testing should follow the program's written policies and might consist of preemployment testing and testing for cause. Programs can ask applicants for counseling positions about their recovery status if the job description and employment policies make clear that abstinence is job related. (For information on a drug-free workplace, visit workplace.samhsa.gov/home.asp.)

Programs need to address the issue of staff drug use. A member of the professional staff who is impaired as a result of substance use may affect adversely the recovery of his or her clients, exposing the program to liability for malpractice. A program's reputation and standing in the community may be damaged by a counselor who is abusing substances. Personnel policies should detail expectations and rules of conduct for professional staff and should explain disciplinary procedures and consequences of staff misuse of alcohol or use of drugs. Integrating job descriptions, personnel policies, and policies regarding relapse and substance use by staff will make it easier to implement or enforce action in difficult or ambiguous situations. Establishing these policies is complicated because Federal (and many State) laws that prohibit employment discrimination treat alcohol abuse differently from drug abuse (see exhibit 3-2). Programs drafting policies for relapse and substance abuse by employees should consider the following issues:

- Distinguishing between alcohol abuse and use of illegal drugs. The law does not protect staff members who use illegal drugs but does protect employees abusing alcohol if they can perform the essential functions of their jobs and do not pose a direct threat to health and safety. Programs must decide whether to treat relapse involving illegal drugs the same as relapse that involves alcohol or legal drugs.
- Job performance of impaired professional staff. Written job descriptions should include abstinence and drug-free status as a requirement. Moreover, staff members who have relapsed or begun abusing alcohol are likely to be unable to perform the essential functions of their jobs and may well pose a direct threat to clients' health and safety.
- Whether to provide incentives for employees to come forward. Programs should consider establishing incentives for employees who are experiencing a relapse to come forward voluntarily and obtain help.
- Treatment for a staff member who returns to work after regaining abstinence. The program needs to determine how much time must pass before an employee may return to work. The program also should decide how much increased supervision will be provided and for how long.

### Staffing To Meet Diverse Needs

#### Culturally diverse staff

A program will benefit from a culturally diverse staff. This diversity needs to encompass all levels in the organization, including the administrative, clinical, and support staff members, as well as the board of directors. A challenge facing treatment programs is how to recruit, attract, and hire sufficient people from different groups. Chapter 4 suggests a number of recruiting and hiring strategies.

#### Special staffing needs for affinity groups

Affinity groups are clients with common characteristics that affect treatment; they include women, adolescents, and clients with co-occurring disorders. Women-specific programs are concerned about setting up a supportive environment in which female clients can feel empowered, learn coping skills, and address issues of physical, emotional, and sexual abuse. Such programs employ primarily women at all levels, which can create an environment that allows female clients to feel more comfortable discussing their lives and that provides role models of responsible, professional women (Weissman and O'Boyle 2000).

### Staff Structure

Carefully formulated staffing structure, clear organizational relationships, job expectations, and a staff communication system are important to a supportive work environment. Management should provide staffing that is tailored to the clients the program serves and accommodates the personal lives of the staff members.

Issues to consider when formulating staff structure include the following:

- Some clients come from highly supervised inpatient settings to the less restrictive OT environment. Staff may face resistance and acting-out behavior as clients adjust to treatment. Some clients may test the limits of the program and their counselors. Staff members need to be prepared for and equipped to treat recalcitrant clients.
- Clients benefit from continuity with the same staff members from assessment through completion of treatment. Clients tend to drop out when they are transferred from one clinician to another. One study found that pregnant women in an outpatient program benefited when continuity was provided in both counseling staff and group membership from the time of the women's inpatient assessment through the IOT and stepdown phases of treatment (Weisdorf et al. 1999).
- Program staff often may provide services during evening and weekend hours. The program needs to be flexible enough to accommodate the personal and family needs of individual staff members.

#### Staff size

What is an appropriate staff-to-client ratio? Because programs vary widely, it is impractical to state specific guidelines for staffing levels. However, the consensus panel reports having IOT staff-to-client ratios ranging from 1-to-8 to 1-to-15. Factors to be considered in establishing counselor caseloads include

- State regulations that govern staff-to-client ratios
- The type of care provided
- The availability of auxiliary services
- The amount of work that staff members can accomplish given their schedules (e.g., a part-time employee should not be given caseload responsibilities requiring 40 hours per week)

### Organizational Relationships and Job Expectations

The program's organizational structure should be articulated clearly, and staff members should have the assurance of knowing exactly what is expected in their roles, job responsibilities, and reporting relationships. The following elements of an organizational structure are recommended:

- An organizational chart. This chart displays current reporting relationships among staff. Management ensures that the chart is fair and monitors it for compliance.
- Job descriptions. Each position has a job description that outlines its responsibilities and functions. The description identifies the knowledge, skill, certifications, and any other necessary qualifications required. The job description is the basis for performance evaluations, with clearly defined expectations and performance levels. These performance indicators are measurable and change as the responsibilities of the job, activities of the program, and the capabilities of the staff change.
- Established evaluation process. The process for evaluating job performance should be identified clearly and followed. This process includes formal assessment and review of a staff member's skills, knowledge, strengths, and weaknesses. Other evaluation measures include
  - Direct observation of clinical sessions by the supervisor
  - Documentation of the training sessions attended
  - A plan for future training and professional growth
  - Formal notification of areas for correction
  - Formal and informal processes for staff review of management

### Staff Communications System

A program needs a comprehensive plan for communicating information among all staff members. The multidisciplinary team approach necessitates good communication among all team members, so they are knowledgeable about each client and can work together. Also, all staff members need to be kept up to date on protocols in a crisis, emergency, or disaster.

#### Staff meetings

Convening routine, structured meetings is recommended. These regular meetings can address the concerns of staff members and provide training on clinical and administrative issues. Staff meetings should focus on reviewing the therapeutic effects of the current treatment plan and determining the need for service adjustments.

As frequently as circumstances permit, case reviews should be conducted to review client progress. Regular meetings bring all involved staff members together to assess each client's status, brainstorm treatment strategies, and coordinate services. Through these meetings, the team can discuss and plan for ancillary services such as housing, employment, health care, mental health care, and family counseling.

Unstructured team meetings and informal “huddles” are valuable in maintaining continuity of care. Staff members should be encouraged to ask for brief meetings whenever there is a need. For example, holding a meeting at the end of a stressful day allows staff members to discuss their feelings, problems, and complaints before another workday begins. Nightly huddles also give staff members a chance to discuss followup plans for clients who did not show up that day and to work through clinical events or client problems that require immediate attention.

#### Administration feedback to staff

In many organizations, administration has knowledge that is not passed along to staff. Issues that should be shared with staff, but often are not, include program performance, policymaking, competitive status, and finances. Counselors benefit from involvement in negotiations or discussions with managed care organizations (MCOs) and from participation in required authorizations, case reviews, utilization reviews, and social or educational events with MCO staff. Increasing the information available to the clinical staff translates into better care for the client.

#### Staff teambuilding

Regular retreats can help promote teamwork. At a retreat, clinicians are away from the stress of the job and can concentrate on teambuilding. A retreat reinforces the idea of employees as stakeholders of the program, involved in management and decisionmaking. Retreats should have a clear agenda, objectives, and anticipated outcomes. Often, programs try to accomplish too much during a retreat. The consensus panel recommends that the agenda for a retreat focus on one or two program planning issues.

## Selection of Qualified and Competent Clinical Staff

Research shows that the therapeutic alliance is a critical factor in treatment (De Weert-Van Oene et al. 2001). Counselor empathy can have a profound and positive effect on client outcomes (Miller and Rollnick 2002).

Research also suggests that the ability to be an effective counselor may be more the result of experience than of academic training. In a National Institute on Drug Abuse (NIDA) study of collaborative cocaine treatment, individual and group drug counseling by experienced treatment counselors was more effective in reducing overall drug use than two types of professional psychotherapy conducted by trained therapists who had less experience treating clients who were substance dependent (Crits-Christoph et al. 1999).

### Qualities of Effective Counselors

Arnold M. Washton (1997), a pioneer in the early design of IOT programs, listed the following qualities of effective counselors:

Skilled clinicians who can be warm, empathetic, tolerant, nonjudgmental, flexible, focused, firm, and clear will be the most effective. Choose counselors who are good motivation mobilizers and change facilitators. These are people who like doing counseling and know how to talk to the patients with empathy and concern. They focus on patients' strengths rather than weaknesses. They are eternal optimists and not easily frustrated. They maintain clear boundaries, but do not come across as distant. (pp. xxvi–xxvii)

#### Personal qualities

To work in a stressful, changeable environment, staff members need to be emotionally mature, adaptable, and creative. They should have the capacity to relate effectively to others and to confront and resolve their own personal difficulties, show self-respect and respect for others, and be willing to learn about and understand people with backgrounds different from their own. They should be capable of taking advantage of mentorship, learning from criticism, and adapting to new approaches. They should be eager to examine their prejudices and able to avoid overidentification with clients.

#### Addiction knowledge

All treatment professionals, regardless of professional identity or discipline, should have a basic understanding of addiction that includes knowledge of evidence-based practices, pharmacology, and the biological bases of addiction.

#### Certification and credentialing

Programs need to recognize one or more certifying bodies for their professional staff. When hired, clinical staff members should be certified, licensed, or working toward certification or licensure in their discipline, with attention given to training in the addiction field.

Staff members should obtain credentials in addiction treatment and have a professional development plan to ensure compliance with internal privileging standards and those of credentialing bodies such as NAADAC and the American Society of Addiction Medicine.

#### Clinical competence of counselors

Clinical staff should meet counselor standards established by the International Certification Reciprocity Consortium and by State addiction counselor certification boards. In addition, staff members should be aware of best treatment practices as determined by research-based evidence. Programs should have counselors who are licensed or certified to treat co-occurring (substance use and mental) disorders.

Programs that have no affiliations with providers of ancillary services benefit from having staff members who are capable of providing a wide range of services. Staff should be able to demonstrate competence in the following areas (CSAT 2006a ):

- Clinical evaluation
- Treatment planning
- Referral
- Services coordination
- Counseling
- Client, family, and community education
- Documentation
- Professional and ethical responsibilities

Appendix B in Addiction Counseling Competencies: The Knowledge, Skills, and Attitudes of Professional Practice—An Update to TAP 21 (CSAT 2006a ) lists the competencies that form the foundation for professional treatment of substance use disorders.

Clinical evaluation skills.Staff members should have a clear understanding of how to evaluate a client clinically, including screening and assessment. They should understand that the diagnostic process is a framework for identifying appropriate treatment. To perform diagnostic functions, staff members need to establish rapport with clients, manage crisis situations, and determine when additional assistance is needed. Staff members also need to identify their own biases and understand how their values and beliefs may affect both communication with clients and their treatment recommendations. Clinical staff also should be knowledgeable about

- The use of current screening and assessment instruments and the interpretation of their results
- The effect of cultural diversity on information gathering and on the assessment of client needs
- Mental status assessment criteria
- Confidentiality requirements

Staff members should know the symptoms of intoxication, withdrawal, and toxicity for all psychoactive substances, as well as the physical, pharmacological, and psychological implications of substance use and abuse. Staff members should be able to assess client readiness for treatment and accept the client's assessment, even if the client is not ready. The clinical staff is expected to use appropriate matching and placement criteria, as well as the current Diagnostic and Statistical Manual of Mental Disorders (American Psychiatric Association 2000) or other accepted diagnostic standards.

Counselors should be familiar with theories about how clients change their substance abuse behavior, as well as how to assess their readiness for the treatment process. Motivational interviewing techniques can help increase the readiness of clients for treatment (CSAT 1999b ; Prochaska and DiClemente 1986). Using assessment data and other information gained from interactions with the client, counselors determine the client's readiness for change and what will help the client use treatment effectively. Counselors also identify barriers to treatment and recovery.

Treatment planning skills.The following competencies are needed to plan treatment well:

- Effective communication and collaboration skills. The counselor communicates effectively with the client, the client's family, and colleagues. It is important for the counselor to explain treatment implications to both the client and the client's significant others, working with them in a collaborative effort.
- Planning, priority setting, and evaluation skills. The counselor works with clients to define and prioritize their needs. For each need, the counselor formulates a measurable outcome. These outcomes are the basis for treatment evaluation.
- Knowledge of treatment options and resources. The counselor develops an individualized action plan, in collaboration with the client. To design the best plan, the counselor should understand all available treatment modalities and community resources consistent with the client's diagnosis and demographic background (e.g., race, age, gender, ethnicity, ability, and sexual orientation).

Referral skills.Many clients need referral for social services. To provide adequate service, clinical staff should use community support systems and other providers effectively; this activity involves understanding the continuum of care. Many clients have been involved in the legal/medical/treatment network previously and may have complicated histories. Some clients may need to be referred for crisis intervention related to mental disorders, for indepth mental status examination, for medication assessment, or for other reasons.

Services coordination.Services coordination depends on the counselor's ability to manage cases, advocate for clients, coordinate community resources and treatment services, and work within managed care systems.

Counseling skills.Several fundamental counseling skills are common to individual and group counseling:

- The ability to establish rapport and engage with the client. Counselors and other clinicians should be direct and nonjudgmental and treat clients with respect.
- The ability to recognize whether counseling and other therapeutic interventions are working. Counselors should have an awareness of the client's reaction to the therapeutic process and of their own reaction to the client.
- The ability to integrate therapy with events occurring in the client's life. Staff members should be comfortable becoming involved with the client's family, employer, and community if permission is granted.
- The ability to know when to seek help from other professionals or a supervisor.
- The ability to educate clients about addiction and recovery.
- The ability to help clients build and practice recovery skills.

Counseling family members of clients requires counselors to understand how substance use affects family dynamics. Counselors should also be adept at engaging family members in the treatment process.

Family involvement is an important but often overlooked component of treating a family member who abuses substances. Staff members who provide family therapy should have supervised experience with family therapy. Family specialists working with clients who abuse substances should have a thorough knowledge of family support in the community and social services, such as Al-Anon and Nar-Anon. Strategies that support clients in recovery and improve family communications and functioning are also valuable.

Client, family, and community education.Education is an integral part of a treatment program's activities, whether the audience is clients, family members, or the local community. Suitable topics include

- Factors that increase the likelihood of substance use disorders
- Signs, symptoms, and course of substance use disorders
- Continuum of care resources that are available
- Principles and philosophy of prevention, treatment, and recovery

Documentation.Substantial documentation is required for most agencies to be in compliance with regulatory and funding agencies. Clear documentation also serves important clinical goals essential to the treatment process. Because of time constraints, counselors need to balance requirements for thoroughness and accuracy with pressures to be productive.

Professional and ethical responsibilities.All staff members, and counselors in particular, have access to extremely sensitive personal information about clients. Because of their knowledge of the client and their professional role, they hold significant power over clients, who may be vulnerable because of their criminal justice or employment status. Consequently, staff members need to adhere to their professional and ethical obligations.

### Recruiting and Hiring Staff

The hiring of qualified staff is critical to the successful treatment of the client, and this responsibility is best shared by several members of the treatment team. Skilled, capable staff members keep the program running effectively and efficiently. Ill-prepared, incompetent, and dysfunctional staff members will compromise client care and the existence of a program.

Programs face a shrinking pool of applicants because of the increasing demand for trained counselors. Just as clients need to be matched to the most appropriate treatment modality, so do staff members need to be matched to an appropriate type of treatment setting and service delivery system. Some questions to consider include

- Does the applicant have experience in the program's treatment modality?
- Does the applicant have experience working with the types of clients served in the program?
- Does work experience suggest that the applicant will be able to function competently with all the program's potential clients? A staff member should be able to treat a diverse client population and prevent personal assumptions and biases from affecting outcomes.
- Is the applicant knowledgeable about addiction, recovery, and the maintenance of a therapeutic alliance?

#### Recruiting applicants

The consensus panel recommends that programs be forward thinking in their search for new staff.

Advertise the position broadly.Many candidates are identified by word of mouth, so programs should network with people who may know candidates both locally and regionally. They should be sure to consider Internet job sources, such as Monster.com and Hot Jobs. Some potential resources include

- National sources such as the Addiction Technology Transfer Center (ATTC) Web site (www.nattc.org)
- An ad placed in the NAADAC Career Classified Ad Program (www.naadac.org)
- Ads in local newspapers, including neighborhood papers
- An ad in any Single State Authority (SSA) newsletter or Web site
- State certification boards
- An announcement through the State provider association
- Announcements to pertinent local and State chapters of professional societies
- Announcements to the psychology and social work departments of local colleges and universities

Use special efforts to find ethnically diverse staff.To counteract the shortage of trained counselors from minority groups, the consensus panel suggests the following:

- Plan to train young candidates. Programs may need to hire young candidates; a young person will require more training than will an experienced candidate.
- Acknowledge that competent minority candidates are highly marketable. Trained minority counselors, especially those who are multilingual, are in high demand. These candidates should be recruited creatively. If the program cannot pay a high salary, administrators should provide a sign-on bonus and try to retain these counselors.
- Identify special resources. Some States now provide funds to train counselors from minority groups. The SSA can provide more information.

#### Interviewing and assessing the candidate

When interviewing candidates, a program should look for the qualities of effective counselors mentioned earlier in this chapter.

A team assessment process.A recommended way to be sure that a candidate can work as part of a team is to have the clinical staff participate in the selection process. Here is a sample interview process.

1. Staff members interview candidates before the clinical director meets with candidates. Part of this interview can be a role play of a counseling session to give staff a sense of how candidates would work with clients. The clinical director can set up the framework for staff to use in evaluating candidates, including
  - Objective criteria for evaluating a candidate.
  - An interview form to score candidates (see exhibit 3-3). This interview form can be modified to reflect the characteristics that the clinical director and staff would like to see in the new hire.
2. The clinical director interviews the candidates recommended by staff.

Checking applicant credentials.An applicant's references should be contacted to verify prior employment and elicit comments on the person's qualities as a counselor. Educational achievements can be verified. Some States require that agencies verify the credentials of their staff and obtain checks for criminal and child abuse convictions. In addition, it is important to run background checks on all employees being hired for drug and alcohol treatment programs.

Applicant's recovery status.Individuals who are not in recovery may claim to be in recovery, thinking that it will enhance their chances of being hired. Rather than asking applicants whether they are in recovery, it is better to ask questions designed to assess their knowledge of mutual-help recovery. For example, the prospective counselor might be asked, “If a client tells you she is having a tough time with the Third Step, what might her issues be and how might you respond?” Knowledge-based questions provide important information about how the candidate will perform as a counselor, and they avoid discrimination based on recovery status, real or feigned.

Exhibit 3-3. Counselor Interview Form

Before scheduling an interview, review the following over the phone:
1. Working hours (e.g., three evenings a week plus Saturday)
2. Salary range for the position
3. Whether the candidate has transportation to get to work
Candidate's Name:_________________________________ | | Date and Time:__________________________________
Credentials:_____________________________________________________________________________________
Scoring Key: 0 = Poor 1 = Fair 2 = Good 3 = Excellent
Characteristic | Score | Comments
Years of IOT experience
Years of OT experience
Total experience with drug and alcohol treatment
Professionalism
Interpersonal skills
Understanding of mutual-help groups
Addiction treatment training
Computer skills
Experience with managed care
Mental disorder treatment experience
Enthusiasm
Other
Total Score: | Additional comments:
Availability (Hours? Start date?): _____________________
Interested in: ___ Full time ___ Part time ___ Either
Experience Using Addiction Severity Index Yes _____ No _____
Salary Requirements: ______________________

## Staff Supervision

Clinical supervision needs to be integrated fully into program management. Ongoing clinical supervision benefits programs by improving care and staff performance. Evidence suggests that clinical supervision is the most appropriate way to reduce staff stress, increase motivation, mobilize for crisis intervention, and provide ongoing evaluation of skills and knowledge bases (Powell and Brodsky 2004).

### Responsibilities of Supervisors

Ongoing supervision that is responsive to staff needs should be provided regularly. Supervisors need training in supervisory techniques and adequate time to supervise. Senior counselors can share in supervisory duties if their caseloads are adjusted to allow them time for both duties.

Supervisors perform the critically important role of educating, encouraging, guiding, and monitoring staff. Supervisors in small clinics may maintain a caseload, whereas those in large clinics may have little or no direct client contact. Supervisors may serve as leaders on performance improvement teams (see chapter 6) and help staff members focus on the organization's mission, goals, and objectives.

#### Supervisory issues with addiction counselors

Powell and Brodsky (2004) suggest that supervisors be particularly concerned about the following:

- Relationships between recovering staff and clients
- Professional credibility
- Cultural bias and unfair treatment
- Staff performance evaluations
- Liability concerns
- Impaired counselors

#### Supervision of specific team members

Medical staff.Physicians and nurses need to be supervised by peers in the medical profession. If the organization does not employ anyone qualified to supervise medical staff, a peer review can be arranged. Clinic directors supervise medical staff on administrative issues, but not on medical care.

Part-time staff.Part-time staff members should meet regularly with either their supervisor or the team. Supervision should be part of the employees' paid work plan; approximately 1 hour of supervision should be allotted for every 40 hours of service. Suggestions for supervision include the following:

- Be flexible so that supervisory hours vary as the person's work hours increase or decrease.
- Schedule supervision intermittently, planning for about 30 minutes every 2 weeks.
- Assign part-time staff to work with particular clients; the primary therapist for those clients then becomes the part-time person's de facto supervisor.
- Allow full-time staff members to supervise senior part-timers who carry their own caseloads. In some cases, a part-time staff member also may have a private practice or an affiliation with another agency. Supervision and program policy should address any resulting conflict of interest regarding referrals.

When more than one part-time staff member works with a client, frequent and regular communication is essential. Good progress notes should serve as the main means of communication among the clinical team.

Peer extenders.A peer extender is a noncredentialed paraprofessional, such as a recovering program alumnus. The peer extender assists clients by acting as a “temporary sponsor” for them in Alcoholics Anonymous (AA) or other mutual-help groups and by taking them to support meetings. Peer extenders also may work as cotherapists or assistant therapists and need to be trained and supervised. Using recovering peers in a clinical setting has legal implications in terms of both confidentiality and professional boundaries. Peer extenders should receive training as follows:

- Confidentiality. Confidentiality requirements apply to both staff members and volunteers. Peers may see clients at mutual-help group meetings and should avoid violating confidentiality. For example, when seeing a client at an AA meeting, the peer should not say, “I'm so glad to see that you're out of detox.” The client may volunteer particulars, but the peer is bound by the same confidentiality laws as clinical staff.
- Professional boundaries. It is important to set clear professional boundaries for peer volunteers regarding clients. A program needs to set up policies that prohibit peer volunteers from becoming romantically involved with clients. One director recommends that peer volunteers sign ethical guidelines specifying no romantic involvement until a client has been out of treatment for at least 3 years.

#### Methods of supervision

The supervisor should meet with all the clinicians to review cases on a regular basis, at least monthly. The overhead cost of these group supervision meetings can be built into the program's budget. Individual supervision, no matter how brief, also should occur regularly.

It can be both interesting and informative to use a variety of supervisory methods. Options include case studies, chart reviews, presentations by outside experts, and videotapes and audiotapes.

Group supervision.The basic group supervision/case review format is cost effective and efficient because the entire team learns together. This format allows clinicians to ask for input from their colleagues, with the whole team solving specific problems or reviewing current cases or issues. A clinician presents a difficult case, describing the problem, diagnosis, treatment history, and course of treatment. Case review sessions increase the team members' skill in working with clients and promote consistency and quality control in treating clients. Other activities for group supervision sessions include a brief presentation on a treatment resource or evidence-based practice.

Individual supervision.It is important for each clinician to meet regularly and privately with his or her supervisor. These meetings can be brief. Regular supervision sets up a climate of learning and inquiry concerning cases—much preferable to the common practice of holding clinician-supervisor meetings only when there is a problem. Individual supervisory sessions should be an ongoing dialog about how best to treat clients and how to manage pressing treatment issues. However, these individual sessions also should focus on staff development and plans for continual improvement.

### Other Roles of Supervisors

Supervisors may fill in for sick counselors, recruit new staff, and review and complete paperwork. A thorough description of the roles and responsibilities of the clinical supervisor is beyond the scope of this chapter. Other activities of supervisors are discussed in chapter 6 on performance improvement.

Suggestions for Supervisors
1. Praise publicly.
2. Criticize privately.
3. Listen.
4. Ask questions.
5. Focus on solutions and on best practices.
6. Work to improve supervision skills.

## Continuing Education and Training

An environment of learning and inquiry is appropriate for substance abuse treatment—a field now driven by the push to adopt evidence-based practices. A spirit of learning and ongoing professional improvement motivates staff and boosts morale.

It is recommended that treatment providers, regardless of their specific discipline or amount of experience, participate in continuing education and training. The consensus panel recommends that programs offer educational and training incentives to their staff members.

### Continuing Education

All counselors and supervisors should assess their own knowledge and skills and then develop an individualized professional development plan. Professional goal setting is a vehicle for improving staff skills and competence, motivating staff, and counteracting stress (see exhibit 3-4).

Exhibit 3-4. Sample Plan for Staff Education and Training

Staff Assessment and Planning Form
In the interest of your continuing professional development, we'd like you to take a minute to complete the following form.
Name:____________________________________________ | | Date:____________________________________________
1. Have you completed at least 6 hours of HIV/AIDS education? | | Yes □ No □
If yes, when?______________________________________________________________________________
2. Have you completed at least 4 hours of tuberculosis/sexually transmitted disease and related subject training? | | Yes □ No □
If yes, when?______________________________________________________________________________
3. Have you been certified in CPR and first aid training? | | Yes □ No □
If yes, when?_______________________________________________________________________________________
4. Review the following topic list and rank each topic on a scale of “1” (no need for more training) to “10” (significant need for training).
Educational Topic | Your Rating | Supervisor's Rating | No. of Hours in Last Year's Plan
a. Supervision and employee evaluation
b. Confidentiality
c. Fiscal management
d. Program administration
e. Program planning
f. Performance improvement
g. Program licensure
h. Personnel management
i. Cultural and diversity issues
j. Sexual harassment and related issues
k. Computer skills
What other topics (or specific issues within the above topics) would you like to learn more about? (Use other side for additional space.)
_________________________________________ | | _________________________________________
Director's Signature | Date | Employee's Signature | Date

Carrying out these plans is challenging because, in many programs, staff cannot get away more than one or two times per year. A program should support education and training for staff by

- Identifying resources needed for an individual's development plan. The administration can inform staff about available resources (see exhibit 3-5 for suggested resources). For example, the administrator may arrange for staff to attend training sessions sponsored by local programs or find out about scholarships for courses.
- Encouraging staff members to be assertive about identifying their education and training needs.
- Being flexible with staff members in negotiating education and training opportunities. Individuals may be willing to exchange their vacation time for inservice training paid by the program. Some programs may be able to support staff members financially in gaining academic credits.
- Tying financial or other rewards to the attainment of an individual's education or training goals, such as academic degrees or professional credentials.
- Making training available on an ongoing basis to all staff members.

Exhibit 3-5. Resources for Staff Education and Training

• Professional courses offered through the 14 regional ATTCs funded by the Center for Substance Abuse Treatment (www.nattc.org). ATTCs have provided millions of hours of academic, continuing education, professional development, and practicum training to tens of thousands of individuals.
• Summer institutes. Many States offer extensive programs for staff training.
• Professional conferences.
• Online education and training.
• Web sites offering training:
| 1. www.motivationalinterview.org lists trainers, as well as an extensive bibliography of abstracts, clinical demonstration videos, training events, and training videotapes in English and Spanish.
| 2. www.tgorski.com lists training and consultation services, publications, workbooks on relapse prevention and denial, and links.
• Distance education courses. A link at www.nattc.org provides a list of online courses from sponsors approved by the ATTCs, NAADAC, and the International Certification and Reciprocity Consortium. This site lists audio/video teleconferences, CD-ROMs, and correspondence, e-mail, and online courses. Courses are listed by topic and language.
• Home-study course books offering continuing education credits. Online booksellers offer the following courses from Red Toad Road Company, with continuing education credits for psychologists approved by the American Psychological Association:
| 1. Addictions Motivational Interviewing with distance supervision available, 12 continuing education units (CEUs), based on the work of Miller and Rollnick (2002).
| 2. Addictions Coping Skills, 10 CEUs, a cognitive-behavioral approach based on a training guide by Monti and colleagues (2002).

### Onsite Training

The program's training plan needs to account for the entire staff, including outreach workers, receptionists, and security guards. The entire staff needs to have some understanding about clients with addiction problems.

#### Training for nonclinical staff

Training for nonclinical staff can be brief but should be tailored to individual roles:

- Security guards. Guards need training in screening people who enter the building. They should have a protective, not intimidating, presence.
- Reception and clerical staff. Training for clerical or administrative staff should include
  - Positive, “customer service” orientation
  - Telephone and reception skills development, using people who have had retail training to teach customer service techniques
  - Role plays of first contact and other interactions with clients
- Outreach workers. Training for outreach workers should focus on setting boundaries between the outreach worker and client.

Training about confidentiality laws should be included for all security guards, clinical staff, and others associated with the program. It is recommended that programs have staff members sign statements of confidentiality that are maintained in personnel folders.

#### Training for clinical staff

Training and professional growth have been associated with increased counselor motivation, improved performance and morale, and decreased stress (CSAT 1999b ; Miller and Rollnick 2002). Staff training programs should focus on topics or approaches appropriate for the client mix (e.g., cognitive-behavioral approaches, co-occurring disorders, relapse prevention, motivational techniques) as well as the identified population served by the agency (e.g., cocaine specific, women's programs, criminal justice).

Manuals and training documents are available for program use in skills development. Many manuals and curriculums have been tested and validated empirically. The lesson plans included in these resources are an asset that can be put to greater use by those in the field. The consensus panel recommends that programs use the materials listed in exhibit 3-6 for training sessions.

Exhibit 3-6. Selected Training Documents

Motivational Groups for Community Substance Abuse Programs (Ingersoll et al. 2000) can be ordered at www.motivationalinterview.org/news/groupguide.html.
Enhancing Motivation for Change in Substance Abuse Treatment (CSAT 1999b ) contains motivational exercises, illustrating how to enhance motivation for treatment in both clients and their family members.
The Matrix Institute on Addictions (visit www.matrixinstitute.org) offers IOT therapist and client manuals as well as other manuals. The institute also offers 2-day IOT training on the Matrix Model for continuing education units.
Managing Your Drug or Alcohol Problem: Client Workbook (Daley and Marlatt 1999) and Managing Your Drug or Alcohol Problem: Therapist Guide (Daley and Marlatt 1997) focus on teaching clients how to manage cravings and reduce the risk of relapse.
A wide range of training documents and client workbook materials is available from the Hazelden Foundation at www.hazelden.org/bookplace.
National Institute on Alcohol Abuse and Alcoholism manuals from the Project MATCH Monograph Series can be ordered at www.niaaa.nih.gov/publications/match.htm. The series includes
| • Cognitive-Behavioral Coping Skills Therapy Manual (National Institute on Alcohol Abuse and Alcoholism 1994)
| • Motivational Enhancement Therapy Manual (National Institute on Alcohol Abuse and Alcoholism 1995a )
| • Twelve Step Facilitation Therapy Manual (National Institute on Alcohol Abuse and Alcoholism 1995b )
The NIDA Clinical Toolbox contains science-based materials for drug abuse treatment and can be downloaded at www.drugabuse.gov/TB/Clinical/ClinicalToolbox.html. The NIDA Therapy Manual Series includes the following volumes that can be downloaded from the URLs listed:
| • A Cognitive-Behavioral Approach: Treating Cocaine Addiction (manual 1), www.drugabuse.gov/TXManuals/CBT/CBT1.html
| • A Community Reinforcement Plus Vouchers Approach: Treating Cocaine Dependence (manual 2), www.drugabuse.gov/TXManuals/CRA/CRA1.html
| • An Individual Drug Counseling Approach To Treat Cocaine Addiction (manual 3), www.drugabuse.gov/TXManuals/IDCA/IDCA1.html
| • Drug Counseling for Cocaine Addiction: The Collaborative Cocaine Treatment Study Model (manual 4), www.drugabuse.gov/TXManuals/DCCA/DCCA1.html
• Brief Strategic Family Therapy for Adolescent Drug Abuse (manual 5), www.drugabuse.gov/TXManuals/BSFT/BSFT1.html

#### Additional training topics

In addition to having knowledge of resources that build counselors' therapeutic skills, administrators should be aware of the following training topics:

- Multicultural awareness. All staff members need to appreciate how their underlying biases and attitudes affect client treatment. Training is required to maintain cultural competence and unbiased clinical service (see chapter 4).
- Aggression management techniques. All staff members need to know how to manage aggression in clients and defuse volatile situations.
- Crisis management. Training in crisis management gives staff members the skills necessary to handle crisis situations. Skills include sound judgment, the ability to assess and respond appropriately, understanding personal limitations, and the ability to stabilize a psychological, social, or medical crisis.

A program needs to train clinicians in recordkeeping, legal matters, and service purchasers' requirements.

Documentation skills.Good recordkeeping is more than a bureaucratic obligation. A program must document its case records effectively for the sake of licensure, utilization review, quality assurance, reimbursement, and program evaluation. The records track program changes, client progress, case planning, and hours of service. They help treatment providers communicate with one another, which is especially critical when a client is transferred.

It is essential that staff be trained comprehensively to document assessments, interventions, treatment plans, transitional notations, and discharge plans. This recordkeeping is both a fundamental responsibility of treatment staff and a requirement for certification. Staff members should receive training in how to document treatment outcomes, using accepted methods and instruments. The training also should cover the following specific elements and skills:

- Regulations about client records
- Essential components of the client records, including release forms, assessment instruments, treatment plans and revisions, progress notes, and discharge summaries
- Client rights
- How to analyze, synthesize, and summarize information, with guidelines for documenting cases in a timely, clear, and concise manner
- Clinical terminology and the practice of objective recording

Confidential and legal requirements.A program needs to ensure that all clinical staff members completely understand program, State, and Federal confidentiality regulations, including when and how to use the appropriate release forms (CSAT 2004). Staff members should understand the basic ethical standards regarding client confidentiality.

Requirements of service purchasers.Clinical staff members need training in meeting the data requirements of purchasing entities, such as MCOs.

## Motivating and Retaining Staff

Staff turnover is disruptive to clinical service delivery and represents a substantial cost in time taken to recruit, select, and orient the replacement staff. High turnover rates may be symptomatic of an unstable, poorly performing program.

### Human Resources Policies

Written policies that show understanding and support for the challenges involved in treatment can be a major factor in staff morale and retention. Following are suggestions for developing thoughtful policies that encourage staff satisfaction.

#### Look at pay scales

Pay scales should be appropriate and reasonable. A program needs to provide fair and competitive compensation that is commensurate with the staff person's responsibility and qualifications. When a valuable staff member receives another job offer, managers should consider making a counteroffer to retain him or her.

One provider reports that salary was the number one reason that IOT, OT, and residential treatment staff members gave for leaving their positions. The average annual salary increase in the new position was $6,000.

#### Recognize challenges

Administrators should acknowledge the stressors and challenges faced by the staff—such as working odd hours in isolation and with limited resources—and establish emotional and structural supports.

Managers should explore opportunities for staff members to do special project work, which can enhance their skills, increase their commitment, and reduce burnout. Such opportunities are possible through staff rotations or through a training swap with other agencies. Business mechanisms that assess performance and award incentives (e.g., 360-degree feedback, in which staff members are evaluated by all their colleagues) are also important. These mechanisms should be connected with both the individual's and the agency's goals. (See chapter 6 for detailed information about using performance measures to enhance staff competence and motivation.)

### Support Within the Work Environment

Part of a program manager's job is to encourage and mentor staff, as well as promote excellence. Managers should function as role models in terms of attitudes and performance. To ensure that treatment staff avoid overwork, burnout, and isolation, managers might

- Use clinical teams so that decisionmaking about clients is a group endeavor, with input from various disciplines. The team assesses and charts progress, plans treatment, and functions cooperatively, putting the best interests of clients first. A supportive, team approach can help reduce staff stressors because responsibility is shared among all staff members. No individual will feel isolated and overwhelmed. It is imperative that staff members have a full spectrum of clinical support services available on short notice and that clinicians know when and whom to ask for help.
- Encourage team building, cooperation, and conflict resolution at staff meetings and retreats.
- Promote a culture of mutual respect by including team members in the decisionmaking process. Replace subjective performance evaluations with objective ones. (See chapter 2 on administration and chapter 6 on performance improvement.)

#### EAP services

Programs should explore contracting with an EAP for their employees. A full-service EAP provides stress management, referral, brief counseling, and critical incident debriefing, if indicated, for staff. Alternatively, program management should have EAP-like policies in place. Such policies should encourage employees to use their mental health benefits if they are having personal difficulties and provide referrals for employees who have problems that interfere with job performance.

#### Flexible and individualized personnel practices

Flexible work schedules can help in recruiting and retaining good staff. It is possible to establish flexible schedules that meet the needs of program operations and accommodate the needs of staff members. Work sharing also may ease caseload problems. Program policy should state clearly which employees are not available for overtime work.

The program needs to have clearly stated policies that demonstrate the administration's concern for staff well-being (e.g., support for time-off requests to reduce stress). Such policies cover mental health days to reduce stress, vacation and sick time, compensatory time, and time to pursue continuing education.

#### Recognition, incentives, and rewards

One cause of burnout is the lack of praise and recognition. The work environment should offer unbiased recognition, reward, and promotion. Supervisors and administrators should look for opportunities to praise the work being done by staff. Some examples are

- The “story” box. Staff members at one program created “stories of ourselves.” Staff members record good things about other staff members and put them in a box. At staff meetings, the stories are drawn from the box and read aloud.
- Performance improvement initiatives. It is helpful to provide objective indicators of accomplishment so that high performers are recognized and those who need to improve can be provided with objective feedback and appropriate direction.
- Incentives. Managers should consider providing incentives for superior performance.

If left unchecked, burnout will adversely affect staff members' commitment to the treatment program and its clients. In addition to recognizing employees' innovations and accomplishments, administrators can mitigate the effects of burnout by giving employees autonomy, communicating openly and clearly, and ensuring an equitable work environment (Knudsen et al. 2003).