# Chapter 2. Management Issues

As outpatient treatment (OT) and intensive outpatient treatment (IOT) emerge as critical components on the broad continuum of care for people who abuse substances, executives are in pivotal leadership roles. They are skilled, informed, and involved in the business of substance abuse treatment. Today's successful executive fulfills a variety of roles while balancing diverse needs and expectations with available resources.

This chapter discusses the challenges facing executives and the opportunities for employing available resources and skills to meet program goals. The chapter includes discussions about

- Roles of the program executive: making the transition from clinician to executive
- Strategic planning and implementation
- Aspects of governance: board of directors and instituting board bylaws
- Program policy and procedure management
- Relationships with strategic partners
- Referring clients to services outside the program
- Sharing new knowledge with those in the field
- Management and administrative issues, such as staffing, policies and procedures, budgeting and monitoring, and facility management
- Program visibility: outreach and public relations

## Roles of the Program Executive

The program executive juggles administrative, clinical, fiscal, policy, and political roles. It is important that the executive carry out these functions within a framework of both effective time management and priority setting. These roles require the executive to

- Provide leadership, vision, and planning for the future
- Manage the internal workings of an office
- Manage increasingly complex human resources
- Handle budgeting and fundraising issues
- Develop and manage formal agreements with other professional service providers
- Develop and maintain relationships with people and groups in the community

No individual is likely to excel in all these areas. However, an effective executive can address these major areas capably and, if necessary, can delegate and oversee the performance of some tasks.

### The Transition From Clinician to Executive

It is common for executives of treatment programs to have served as clinicians before they moved to a chief executive role. This transition from clinician to executive needs thoughtful planning and preparation. Managing a program is a demanding and time-consuming job that requires an array of qualities and skills, including leadership, business sense, human resource knowledge, strategic thinking, budget management, and decisiveness. These are not necessarily the skills a clinician develops while treating clients.

Many clinicians come to their new executive jobs without any formal training in organizational theory and business management. New executives change their focus from delivering clinical services to managing the systems and group dynamics of the workplace. Because many clinicians have little training in management, they may feel uncomfortable in the new role.

Those who have enjoyed clinical careers are sometimes reluctant to relinquish the clinical role entirely (McConnell 2002). Management, however, is usually a full-time job. New executives realize that managing the program is now their first priority and primary responsibility. The demands may preclude clinical work. However, some executives deliberately maintain a few cases to keep in touch with clinical issues, maintain their clinical skills, and model behaviors and practices for clinical staff.

## Strategic Planning and Implementation

Strategic planning should be thought of as a regular, periodic activity—as important when the program has been in operation for years as when setting up a program. Preparing a strategic plan is a time-consuming but necessary process that can help a program in the following ways:

- Provide direction when starting a program.
- Define or revise the program's mission and directions.
- Set clear program goals.
- Ensure that resources are invested effectively.
- Find cost savings and new resources.
- Energize the board and staff, improving morale and performance.

The discussion that follows will benefit executives of both new and existing programs. The Addiction Technology Transfer Center (ATTC) Network has compiled The Change Book: A Blueprint for Technology Transfer (ATTC Network 2004a ) to help programs implement change initiatives that will improve client retention and treatment outcomes. The Change Book and The Change Book Workbook (ATTC Network 2004b ) can be ordered or downloaded at www.nattc.org/respubs/changebook.html.

### Strategic Planning Parameters

Before embarking on the development of a strategic plan, the executive should consider the following:

- The participants who will develop the strategic plan. A consultant can be helpful if resources are available to hire one. If potential board members and funders of the program have already been identified, their input should be sought. The strategic planning process for an existing program should involve members from every level of staff as well as clients because these people will present different perspectives and will be the ones affected by the decisions that are made.
- The period covered by the plan. How far into the future should the plan project? Strategic plans can span virtually any period but generally cover at least 1 year and often extend over 3 to 5 years.
- The amount of time devoted to the planning process. The amount of time individual participants are able and willing to allocate to the process will vary. It is helpful to establish a schedule of activities and a target date for completing the plan.

### Developing a Strategic Plan

There are many different approaches to strategic planning, but some common steps include

- Conducting a community audit or needs assessment. What kinds of treatment needs are going unmet in the community? Is there a special treatment niche that needs to be filled, such as treatment for adolescents or women with children? A first step is to perform a community audit or needs assessment. The Single State Agency (SSA) may have a State Needs Assessment for the area that will provide some information. However, if a program defines its targeted group too narrowly, its ability to treat a population with a substance-dependence problem may be limited, restricting the number of clients. Therefore, the program should be designed to provide a wide range of options and with the potential to broaden services.
- Identifying comparative program strengths. How do the program's strengths and weaknesses, scope of services, populations it serves, convenience of location, response time, cost to the client, and links to other services compare with those of other programs in the area? After analyzing the strengths and weaknesses, a program might determine it has a competitive advantage in marketing its services to managed care companies because it offers comprehensive services or can admit clients within 48 hours. Or a program might have an impressive track record treating clients who are referred by the criminal justice system. Another program might find it needs to change staff hours to be able to attract people who are employed and can attend treatment only in the evenings or on weekends.
- Developing or clarifying the program's mission and core values. Everyone in the program should understand and support a common vision of the program's goals and values.
- Developing and evaluating goals. An effective strategic planning process results in clear, measurable, prioritized goals. There should be discussion of whether the goals are realistic, given the program's expertise, time commitments of staff, available funding, and other resources required to reach the goals.
- Identifying strategies to achieve the program's goals. Planners should develop multiple strategies for reaching each goal, evaluate each strategy's merits and drawbacks, and select the strategies to pursue.

The executive can assist those participating in the strategic planning process by preparing guidelines that address the following issues:

- Maintaining a collaborative process. The participants need to be able to exhibit mutual respect, professionalism, openness, and patience. The best thinking is done in a safe and supportive environment.
- Staying on task. The participants need to stay focused on the most important items and avoid getting lost in details or side issues.
- Accepting consensus when unanimity cannot be achieved. Although it is important that participants entirely support the process and its result, compromises may be required to reach consensus.

### Implementing the Strategic Plan

The completed strategic plan describes the goals the program hopes to reach. The next step is to draw up an annual operating plan, which describes the actions required to meet each goal and who is responsible for performing those actions. The executive should involve the entire staff in implementation, delegating responsibility for implementing the operating plan and communicating enthusiasm and support for the vision laid out in the plan.

The executive oversees implementation of the operating plan and removes barriers to its execution. Outcome measures that reflect the strategic plan's individual goals are tracked. Progress toward each goal then can be assessed, and the operating plan can be adjusted as necessary.

## Board of Directors

A program needs a board of directors to monitor the internal and external management of the organization. This level of governance is extremely important for a successful business venture. Some experienced providers believe that the selection and use of boards are the weakest areas in the administration of treatment programs. Requirements vary by State, but many jurisdictions require nonprofit organizations to have a board of directors. The board is responsible for

- Overseeing the program's operating procedures, budgets, and fiscal controls
- Approving the program's mission and long-range plans
- Monitoring the executive's performance

Board members also help with fundraising and represent the program in the community, acting as ambassadors for the organization and explaining the community to the program. (See exhibit 2-1 for a sample statement of board members' responsibilities.) Board members should be committed to the program's mission and willing to contribute the time needed to be responsible stewards of the program. The board of directors in a nonprofit program needs to work as a team with the executive and staff to support the program's mission and future success.

Exhibit 2-1. Sample Statement of Board Member Responsibilities

General Responsibilities
• Appoint and annually evaluate the executive director
• Attend all meetings of the board of directors
• Set organizational policy
• Approve and monitor the annual budget and plan
• Develop a mission statement, and review it periodically
• Establish a strategic plan for the program (to ensure future success)
• Evaluate organizational effectiveness in accomplishing board-approved objectives
• Serve on at least one board committee
• Become informed and educated about the program and the industry of which it is a part
• Be familiar with the program's bylaws
Fundraising Responsibilities
• Actively participate in special events sponsored by the program
• Help raise funds for the program using creative strategies
• Optional: Make an annual personal donation to the program
Public Relations Responsibilities
• Act as a sounding board for community feedback about the program
• Serve as a liaison to other community organizations
• Support the services of the program, and speak out on its behalf

Nonprofit board members may be responsible financially if the program fails and debts are incurred. The executive must advise prospective board members about this liability. A program should consider purchasing liability insurance to protect board members against potential liabilities.

### Choosing and Encouraging Board Members

The majority of board members should have some knowledge or understanding of substance abuse treatment. If the program is publicly funded, it is useful to have board members with connections to all important political parties at the State and local levels. If the program relies on reimbursement from insurance companies and managed care companies, it is helpful to include board members with expertise in those areas. The consensus panel suggests that boards contain at least one representative from the local community and from the program's constituency (including both clients and referral sources).

Members with fiscal and legal expertise are excellent additions. Members from the nonprofit and foundation worlds can provide perspective on management and funding issues. The board also should be diverse with respect to gender, cultural background, and sexual preference.

When recruiting new board members, the executive, along with one or more board members, should meet with prospective members to determine how well they would serve the program and whether they are willing to devote the necessary time to the board. At the meeting, the executive should be frank and honest about the responsibilities of board members and discuss the following:

- The organization's goals and needs
- The preferred skills and qualities of a board member
- The expected time commitment
- Personal-giving expectations, if any

Prospective members will need time to decide on this serious commitment. Receiving a “no” is better for a program than having a board member who is unable to give the needed time and effort.

Effective boards are the result of ongoing planning and effort, effective teamwork, and a high level of commitment. Some helpful strategies follow:

- Orientation for board members. New board members should be oriented individually or in small groups. They should be provided with a binder of information about the program. A helpful orientation covers such areas as (1) the organization's history, mission, services, and data on service delivery; (2) board composition, responsibilities, and meeting and committee structures; and (3) job description of the program director, schedule of the board's meetings, bylaws, budget, and current short- and long-range plans.
- Ongoing responsibilities. Board members become more committed when they have ongoing tasks and responsibilities. Each member needs to have a specific role, such as committee member, committee chair, or task force member. Exhibit 2-2 lists types of board committees that can be established and typical responsibilities for each.
- Communication. Board members need to be kept informed. They should be provided with updated fact sheets about the program, minutes of board meetings, and printed agendas at regularly scheduled meetings.
- Evaluation of the board. Some executives recommend that an outside consultant evaluate the board's performance at a minimum of 5-year intervals. As terms expire, board members can be asked to evaluate their performance (see self-evaluation form, exhibit 2-3). Self-evaluation is a tactful way of encouraging board members to retire when they are not able to make the expected commitments of time (or money, if this is part of their responsibility) to the program.

Exhibit 2-2. Examples of Board Committee Structure

Standing Committees
• Executive committee. Acts between meetings of the full board; is empowered by bylaws and can exercise all board powers, except changing bylaws; and reports on actions at each board meeting
• Nominating committee. Develops criteria for recruitment, selection, and retention of board members; identifies and approaches potential board members; and develops rotation provisions
• Finance and budget committee. Is responsible for audit and appointment of independent accountants; reviews financial statements; evaluates and approves audit; evaluates organization's ability to manage fiscal and accounting functions; and works with the resource development committee to set adequate funding goals
• Resource development committee. Develops and approves development plan; conducts board-giving campaign; recruits chair for targeted campaigns; oversees all fundraising activities; and educates board in fundraising responsibilities
Optional Committees
• Personnel committee. Sets and approves personnel policies and procedures; approves benefits and compensation policies; and ensures compliance with laws
• Bylaws committee. Monitors compliance with bylaws and recommends changes in bylaws
• Program committee. Approves program plans and activities; participates in new program development; and reviews quality assurance

Exhibit 2-3. Board Member Self-Evaluation Form

To be self-administered before consideration of a second or subsequent term of office as a board member.
1. Have I attended:
| a. All board meetings? | □ yes | □ no
| b. A majority of the meetings? | □ yes | □ no
| c. Fewer than half of the meetings? | □ yes | □ no
2. Have I actively participated on at least one board committee? | | □ yes | □ no
3. Have I made a personal financial contribution to the organization? | | □ yes | □ no
4. Have I served as an advocate for the organization? | | □ yes | □ no
5. Have I kept myself informed about the organization, its role in the industry, and its role in the community? | | □ yes | □ no
Scoring: How do you rate yourself? Use the following scoring chart to assist you: For question 1, score a “yes” response as follows:
1 point for answering “yes” to a
½ point for answering “yes” to b
0 points for answering “yes” to c
Score 1 point for each “yes” response to questions 2, 3, 4, and 5.
Interpretation:
4–5 points—You are great and must continue!
3 points—You definitely should consider continuing, but please try to do a bit more.
2 or fewer points—Please consider not returning; your interests probably lie elsewhere or you're currently overcommitted.

Bylaws are the instruments that nonprofit boards follow to perform their roles. Bylaws establish membership requirements, term limits or rotation schedules, governance structures of board officers and standing committees, and voting procedures. With carefully prepared bylaws, nonprofit boards are able to keep administrative and housekeeping tasks to a minimum, focus on key issues, make necessary decisions, and sustain the interest and involvement of their members.

## Program Policy and Procedure Management

Licensing statutes and accreditation standards require that programs establish written policies and procedures. A key executive responsibility is to ensure that these written policies and procedures meet State licensing requirements and that they are being followed. Policies and procedures should cover the following areas:

- Client care, such as screening and assessment, treatment planning, and discharge planning
- Recordkeeping, including the content and security of clients' records
- Organizational structure, such as governance committees and staff positions
- Fiscal management, including budgeting, monitoring, and reporting
- Personnel, including hiring, evaluation, and termination procedures
- Program structure and staffing, delineating clinical and administrative functions and supervisory positions
- Clients' rights, setting forth the clients' specific rights and the program's grievance processes
- Performance improvement programs, including setting standards, monitoring performance, and using results to improve the program
- Facility, health, and safety standards, including first aid and emergency planning, and a significant disaster management policy

These policies and procedures need to reflect the program's treatment philosophy. Also, in the current funding environment, an executive may want to include the use of evidence-based or best practices as an important issue in program policy and procedures.

### Accreditation

The program executive is responsible for ensuring that the program continues to meet its accreditation and State licensure standards. If the program is not accredited, the program executive decides when, and whether, to seek accreditation.

It is possible for some programs to sustain a specific treatment niche without going through the accreditation process. However, program executives need to consider the possible advantages of accreditation. Accreditation is a growing requirement in the substance abuse treatment field. The Center for Substance Abuse Treatment (CSAT) now requires that all opioid treatment programs become accredited through the Joint Commission on Accreditation of Healthcare Organizations, Commission on Accreditation of Rehabilitation Facilities, Council on Accreditation, or other CSAT-approved accreditation entity. Accreditation places a program in a more favorable position to secure contracts and may be required for State licensure and managed care contracts.

For a program that decides to seek accreditation, the following is suggested:

- Consider forming an alliance with a larger organization that can provide support.
- Hire a consultant with documented accreditation-related experience to assist with the accreditation process.
- Visit www.jcaho.org, www.carf.org, or www.coa.net for more information about accreditation processes and requirements.

## Relationships With Strategic Partners

Although many programs succeed as independent organizations or by providing a single level of care, there are risks to this approach. Establishing linkages, formal alliances, or relationships with other agencies can strengthen a program and can be an effective way to obtain new sources of potential clients. Strategic alliances can take many forms, such as the following:

- A program can provide intake services at the site of a strategic partner. Staff members can be placed in health clinics, welfare offices, mental health programs, emergency rooms, and criminal justice settings to perform screening or initial assessments. For example, a program that stations a staff member in an emergency room may gain new clients (see exhibit 2-4). Similarly, providing information or assessments in the criminal justice process can be effective.
- A program can provide services at a strategic partner's site. For example, a program could place staff members on the site of a mental health care provider. This alliance serves the interests of both agencies, expanding the services each offers and treating clients who have co-occurring disorders in one location. A welfare-to-work program might need a treatment provider to deliver onsite services to its clients, or a high school might be interested in having recovery groups and assessments on campus.

Exhibit 2-4. Example of an OT Program and Emergency Room Strategic Alliance

Emergency rooms in hospitals see many intoxicated patients. One hospital was willing to pay OT program staff to provide assessments on site. Program staff members assessed people who were intoxicated when brought in; staff found this location to be an excellent source of referrals, including patients able to pay on a fee-for-service basis. An OT program staff member
• Interviewed emergency room patients with problems such as intoxication or drug overdose, trauma, and complaints about pain, which could signal drug-seeking behavior
• Interviewed family members, asking about problems or accidents related to substance abuse
• Encouraged family members to get the patient to accept treatment

Marketing can be a key to establishing new alliances. Potential referral sources include managed care companies, employers, mental health services providers, employee assistance programs (EAPs), schools, hospitals, welfare agencies, religious leaders, and criminal justice agencies.

The first step in marketing is to develop a strategy based on the community audit or needs assessment performed during strategic planning. The executive should consider the following points:

- Determine how best to reach the target market. If the target market includes people in crisis, the program could network with other human service providers. If the target is a managed care organization, the program's executive could meet with managed care providers and behavioral health consultants to provide information about the program's strengths. If the program is looking for additional criminal justice clients, the executive could network with prosecutors, defense counsel, court system personnel, probation and parole officers, and coordinating case management entities, such as the Treatment Accountability for Safer Communities. Often contacts need to be made at multiple levels within a referral source. It is important to follow up with referral sources; they should be treated as a major part of the program's marketing efforts.
- Identify the person best able to connect with the target market. The best person might be a board member, the executive, a staff member, or a program graduate.
- Develop materials to leave behind after a meeting.

Once a marketing strategy to identify new alliances is selected, the executive needs to continue the effort. Marketing tends to have a cumulative effect. Not every effort produces results, but some efforts meet with success, and positive results tend to generate additional opportunities. Typically, marketing efforts take 6 to 12 months to reap benefits. A program that initiates a marketing effort after a downturn in business will have a more difficult time than if it initiates its effort when business is good and visibility is high.

Chapter 5 includes additional information about strategic partners.

## Referring Clients to Services Outside the Program

In addition to partnering with agencies that refer clients to a program, the program needs to establish relationships with agencies that supply services not provided by the program.

### Identifying Outside Services

OT executives need to know what services are available in their area. Each community has distinct ways to disseminate information about services. In most places, agencies or organizations regularly publish a directory of available social services and specialty programs. These directories usually are available from local public health departments, welfare councils, Councils on Alcohol and Drug Abuse, United Way chapters, county or municipal governments, public libraries, and regional offices of Federal and State agencies. The local Yellow Pages lists many types of special services under “Human Services,” “Social Services,” and “Drug Abuse and Addiction.” Web sites, newspapers, and professional groups are other places to look for announcements of new services or articles about the success of existing programs.

Some locales have automated directories of social services that are updated continually. Although costly, these directories let the program know immediately when openings become available in regularly used and oversubscribed services.

A program's files need to include information about the following types of services and organizations:

- Adult education programs
- Child care
- Credit counseling programs
- Faith-based institutions
- Family therapists and couples counseling
- Food banks and clothing distribution centers
- Housing resources, including U.S. Department of Housing and Urban Development Section 8 housing, homeless and battered women's shelters, and recovery houses
- Inpatient and outpatient psychiatric treatment and mental health services
- Legal assistance for civil and criminal charges
- Parent training programs
- Preventive health care and both inpatient and outpatient medical services (e.g., visiting nurses; home health aides; physicians; specialty clinics for HIV/AIDS, sexually transmitted diseases, or tuberculosis; and prenatal and pediatric care)
- Public transportation
- Recovery support groups, such as Alcoholics Anonymous
- Recreational facilities and programs
- Social service and child welfare agencies
- Vocational rehabilitation or training and EAPs
- Volunteer transportation services

### Keeping Up-to-Date Files of Resources for Clients

Executives ensure that the program's counselors and case managers develop and maintain a current and accurate list of local and regional services their clients may require. Because fewer options may be available in small or rural communities, treatment programs in these settings need to be creative and assume an active advocacy role in developing new resources and sources for services.

Programs should update files of resources, including each resource's name, address and telephone number, services offered, hours of operation, proximity to public transportation, contact person, eligibility criteria, costs, numbers of persons it serves, waiting lists, and staff qualifications and titles.

The executive needs to implement a mechanism for evaluating these external services. For example, how long is the wait to receive service? Do staff members treat people with substance use problems or people with AIDS fairly? This evaluation may include feedback from clients who are referred to and use the resources. Another option is to institute an exchange program, in which program staff members trade places with their counterparts in other programs. Volunteers can be enlisted to visit community resources, obtain information, and update files.

New services continually are being established while old ones are closing; executives need to inform staff of these changes.

### Developing Formal Service Agreements and System Linkages

The program executive is responsible for establishing and monitoring formal arrangements with other organizations. These arrangements can be written memorandums of understanding, cooperative service agreements, interagency agreements, or legal contracts. Because case managers will follow the formal procedures outlined in these agreements and comply with legal contracts, case managers should be involved in the development of these agreements. The program's legal counsel may need to review the documents. Formal service agreements need to specify

- The types of services offered
- The qualifications of staff members who deliver the services
- The number of slots each participating agency will make available
- The time limits or cost caps on services
- The lines of authority and accountability
- The specific procedures to be followed in making referrals

(See CSAT's TIP 27,Comprehensive Case Management for Substance Abuse Treatment [CSAT 1998b], and Quick Guide for Administrators Based on TIP 27 [CSAT 2001] for more information.)

The community resources that case managers use must meet the needs of the program's client population. In addition, program staff members need to have affiliations with and knowledge about other substance abuse treatment resources in the area. Clients then can be transferred to other levels of care if needed.

## Sharing New Knowledge With Those in the Field

The executive needs to take the lead in informing the program staff about developments in the substance abuse treatment field. A program might plan for regular dissemination of new information through e-mail messages, a staff newsletter, or staff meetings. Some areas to monitor are

- Legislative changes. The Health Insurance Portability and Accountability Act—a new set of Federal regulations governing clients' privacy rights—is an important legislative change (CSAT 2004).
- Clinical and research developments. Research about treatment practices needs to be integrated into treatment practices. Evidence-based information is updated regularly at the Web sites of the National Institute on Drug Abuse (NIDA) (www.nida.nih.gov), National Institute on Alcohol Abuse and Alcoholism (www.niaaa.nih.gov), and the Substance Abuse and Mental Health Services Administration's (SAMHSA's) National Clearinghouse for Alcohol and Drug Information (NCADI) (www.ncadi.samhsa.gov).
- Regulatory developments. The CSAT Web site (www.csat.samhsa.gov) is an important resource for following such developments.
- Developments in funding. It is extremely important for executives to keep up to date about the companies, agencies, and grant programs that fund treatment. (See chapter 5.)

## Management and Administrative Issues

### Human Resources Management

No program can succeed without an enthusiastic, hard-working staff. A major function of the executive is to support the clinicians and the rest of the staff, create a culture that nurtures and brings out their best, provide the resources that will make their work easier, and help staff members become more productive. Management style is important. As one experienced executive points out, a touch of humility and a positive, supportive approach can be the executive's best assets.

Managing the human resources of a program includes the following:

- Providing leadership. The executive leads the board of directors in defining the program's mission and objectives and engages the staff in translating this mission into an action plan. Developing and implementing a program's action plan should be an ongoing, teambuilding process. The collaborative creation of such a plan helps transform a clinic staff into a team.
- Setting policy. The executive oversees the establishment of a written human resources policy, sets pay scales, and establishes benefit packages that are equitable and appropriate.
- Supervising both clinical and administrative staff members. The executive should give clear, decisive direction to staff. Whereas the clinician is accustomed to influencing clients by persuasion and clarification, the executive often exercises more direct means to manage staff. The executive should be prepared to mediate disputes between staff members and provide clinical guidance.
- Providing efficient operations. The executive needs to model efficient, effective operating methods. The ability to conduct productive meetings is particularly important. Well-run meetings focus on agendas, goals, the people responsible for particular tasks, and deadlines.
- Evaluating information technology. Executives should explore updating computer systems and software to reduce costs and increase productivity.

(See chapter 3 for information on recruiting, retaining, evaluating, and providing professional development for staff members.)

#### Keeping in touch with clinicians

The clinician turned executive needs to acquire different skills to be a successful executive and may lose touch with the reality (including the frustrations) of counseling clients and completing paperwork. Ways to keep in touch with the experiences of frontline clinicians follow:

- Run groups on occasion. Executives with clinical experience can step in when a staff member is sick or on vacation and function as clinician for a group. Demonstrating clinical expertise can enhance the executive's credibility with staff.
- Manage by “walking around.” Simply by walking around, an executive can get a good sense of how the program is functioning. For example, the executive can observe and assess how well the work flows throughout the facility. Is the space arranged to promote efficiency? Is equipment easy to use and located where people need it? Are the forms easy to fill out and practical? How comfortable do staff members and clients appear?
- Observe and monitor all clinical duties. The executive needs to check in and observe groups and clinical services for quality assurance, clinical integrity, and adherence to the program mission and purposes. This activity requires returning to the program from time to time to observe clinical work during evening, weekend, or early morning program hours. These observations can help an executive understand any differences that may occur among these various shifts.

#### Expert consultants

A good executive knows when professional advice is needed and makes use of consultants. For example, a computer consultant can design software to improve the documentation process. A human resources specialist can help design a benefits package. A lawyer can draft protocols for reporting child abuse and neglect. A grant specialist can identify funding opportunities and prepare grant applications and other proposals.

Free expert consultant services are available for nonprofit programs. These free services (e.g., through the United Way) include help with board development, strategic planning, and administrative training. The nonprofit corporation CPAs for the Public Interest assists organizations in setting up budget, fiscal, and payroll systems and helps programs prepare for audits.

Consultants can help the executive define the program's philosophy, clarify the program's mission, develop new programs, and translate all of these into written policy. They can help programs establish and plan performance improvement and quality assurance programs and “sell” the importance of the quality improvement process to staff members.

### Facility Management

The executive is responsible for maintaining a facility that is in compliance with local building and fire codes and standards set by the State or accreditation bodies. The facility also should be attractive and comfortable for clients. Whether the clinic is a residential or an OT program, an inviting facility aids in client retention. To create an inviting environment, the program executive should consider the following:

- Ensure that the interior is physically attractive. Furnish the waiting area with comfortable chairs, attractive furniture, and colorful and informative pictures and posters. Recovery-oriented posters are an inexpensive way to decorate. Remove broken furniture, old magazines, or out-of-date announcements. Encourage staff members to decorate their offices in a way that expresses their commitment to professionalism and client care. The executive sets the tone for staff by the way in which the executive's office is decorated.
- Maintain cleanliness. Replace or clean any heavily stained chairs and carpets, and encourage the staff to feel responsible for the facility's appearance. All staff members can help by tidying up the waiting area, throwing away clutter as they move through the common areas, and bringing in cheerful items for display.
- Encourage a nurturing, friendly atmosphere. Complement the motivational clinical strategies that engage and retain clients in treatment with a warm environment. Important ways to create such an atmosphere include
  - Friendly receptionist or office manager. Ensure that the receptionist or others who answer telephones are trained to be supportive and welcoming. Their manner can help create a welcoming, positive experience for the client. The skill of staff members who are in initial contact with potential clients, their families, and other concerned individuals is an important ingredient of a successful outpatient program. (See chapter 3.)
  - Comfortable seating. Offer comfortable seating in the waiting area that is adequate for the number of clients coming in and out.
  - Refreshments. Provide fruit, bagels, coffee, tea, or water. For some clients, food is an incentive to visit the program or to keep their appointments. In addition, some indigent, homeless clients who have chronic illnesses may need to take their medications with food. Providing food may add to program costs, but these expenses can be kept to a minimum by negotiating with local businesses to provide food at a discount.
  - Educational entertainment. Provide materials that are educational and entertaining in the waiting area, such as educational videos, a selection of recent magazines, books that clients can take with them, or a computer terminal with educational programming. Programs can diversify the materials they offer in the waiting room by asking for donations from the community.

### Financial Management

The executive faces the challenge of managing the program's budget while trying to increase revenue, decrease costs, and deliver the best service to clients.

#### Budgeting and monitoring funding resources

The executive tracks actual revenues and expenses, compares them to projections, and makes the necessary adjustments. The program executive should be prepared to seek additional support or to cut expenses during a budget cycle. Tracking accounts receivable is especially important. The executive should be aware of the current financial status of each funding source, know when any account is falling behind, and conduct whatever negotiations are needed to restore revenue quickly.

#### Balancing expenditures and services

The executive who exercises effective fiscal management is attuned to the fact that the program may have services and management structures that no longer serve clients' and the program's needs. The executive should review the program's services and its management structure analytically and objectively, asking these questions: Is every service essential? Is each generating sufficient revenue? Is the service worth what the program charges for it?

To maintain the most efficient, cost-effective operation, the executive may need to change the program's mix of services or restructure staff positions. A challenging task is to strike a proper balance between new opportunities and the program's financial capacity. A balance must be achieved between the following extremes:

- Too many staff members in management roles. If management positions have proliferated, it may be time to eliminate tasks or to consolidate positions in a way that maintains an effective management structure.
- Too little administrative structure. Cutbacks can result in too little management to sustain program integrity and support high-quality clinical services. When cutbacks are too severe, the remaining staff members can be overextended and assigned tasks that they cannot manage. Under these circumstances, hard decisions must be made about which services are essential and which are ideal, but unaffordable.

Some ideas for decreasing costs include

1. Change the service mix. Core program services should be self-supporting. Services that are not self-supporting after 6 months should be reviewed carefully and eliminated, unless they are essential to the organization's mission and other revenue streams are sufficient to underwrite the costs.
2. Change the staffing mix. Several strategies can be considered:
  - Consolidate positions. One program with four large sites originally had hired a manager for each site. When managed care began cutting back on approved treatment sessions, the program executive eliminated all but one of the four onsite management positions and upgraded other staff members to assume the additional responsibilities. A program may be able to consolidate positions by using technology. For example, instead of having individual office managers at each location, the program might have a single manager oversee work at all sites linked through a computer network.
  - “Rightsize.” It is always difficult to let staff members go, but from time to time financial realities make this a necessity. One way to ease the pain of this kind of decision is to give adequate notice and provide letters of reference. Telling staff members that their positions may have to be eliminated within a certain period enables them to begin looking for new jobs while they are employed.
3. Save staff time and labor costs by reducing paperwork. Paperwork is a necessary part of a counselor's job, but filling out forms can take considerable time and brings little value to the client. Simplifying paperwork and eliminating repetitive forms as follows can reduce the paperwork burden for staff and improve morale:
  - Revise the documentation process. Eliminate any forms that require staff to enter the same information multiple times. For example, a program could use one form to establish consent to release a client's information to several different individuals or agencies. (Note that the resulting form will be valid as long as the need for or purpose of the disclosure, the kind or amount of information disclosed, and the duration of the consent are identical for each recipient and each recipient's name or title is specified [CSAT 2004].)
  - Revise forms. Make sure forms are up to date and collect only the information the program needs. Review all forms being used. Whenever possible, replace forms that require people to write in information with checklists that can be filled out quickly. Look at the forms used by other programs, and adopt good ideas from them.
  - Use technology to handle client forms. Computerize recordkeeping to save staff time. Software can be used to record and update treatment plans, progress notes, diagnosis and discharge summaries, and referral planning and progress. Completing records by computer means that many fields, such as client contact information, will be filled automatically instead of being rewritten by hand. Although there are costs associated with making a transition to a computerized system, an automated recordkeeping system can produce substantial long-term savings and efficiencies.
4. Find savings through strategic partners. For example:
  - Increase buying power. Save money on drug testing, human resource services, and supplies and equipment purchases through agreements with other human service providers.
  - Ask a partner to provide a critical service. Find a partner that already provides a service and is willing to serve the program's clients (see exhibit 2-5 for an example).
  - Engage staff. Invite staff members to suggest ways to cut costs; reward their contributions.
  - Find free resources. It may be possible to arrange training for staff at no charge to the program. Both SSAs and CSAT provide training free of charge. Sometimes larger treatment programs allow staff members of smaller agencies to join inhouse training programs.

Exhibit 2-5. Example of Reducing Costs for an Emergency Hotline

IOT programs need to offer 24-hour emergency coverage for their clients. Telephone answering services are often inadequate, however, because they are expensive and not staffed by clinicians. One provider found the following solution:
An urban IOT program agreed to pay a local detoxification center to handle calls from IOT clients on the detoxification center's 24-hour helpline. The center's service was less expensive than an answering service and of higher quality because it was staffed by nurses and addiction specialists who had emergency care knowledge and understood confidentiality requirements.
Both parties benefited from the agreement. The IOT program obtained 24-hour telephone coverage by skilled staff, and the detoxification center received new business because clients requiring hospitalization were admitted to its facility. In addition, a strategic partnership was created.

## Program Visibility: Outreach and Public Relations

An important part of the executive's job is maintaining the program's visibility in the community. Executives who cultivate and maintain strong relationships help ensure that when the program needs support, the program is well known.

### Political Relationships

State officials can help secure funding. Even if a program is funded privately, it probably still is regulated by State officials. Officials who feel connected to the program and its executive are more likely to support a program.

To establish and maintain strong relationships with State regulators and State and private funders, the executive should consider the following options:

- Spend time with officials, getting to know them (and giving them the opportunity to get to know the executive). These encounters can take place through one-on-one meetings, on the telephone, or at conferences.
- Invite officials and funders to attend program functions, such as client graduations. Observing program activities gives officials and funders a clear picture of what the program does, who its staff members are, and the clients it treats.
- Keep the program visible to officials and funders with regular mailings about program achievements. A short note is appropriate when the program wins an award, gets a new grant, joins a new coalition, or is featured in a news story.

The executive should make an effort to get to know local officials (e.g., the town executive, mayor, town council, community board) and attend community board or town council meetings regularly to cultivate relationships with local officials.

### Outreach to the Community

The program has a web of community relationships with neighbors, local groups, clients, and clients' families. The program affects the quality of life in the neighborhood around it, just as the neighborhood affects the quality of the program. A potential benefit of active outreach activities is the opportunity to reduce the stigma associated with a substance use disorder. The stigma of addiction prevents people from seeking help and deters policymakers from providing adequate funding for care. Everyone benefits when a program's outreach presents a positive portrayal of recovery and its effects on individuals, families, and the community.

#### Neighborhood relations

Neighborhoods often do not welcome substance abuse treatment programs. Programs seeking to move to a new location or expand in their current one may encounter resistance from people in the neighborhood. Because of the stigma that substance abuse carries, landlords and communities often have the following fears about treatment programs:

- The program threatens the building's appeal to other tenants or the neighborhood's residential character.
- The building and parking lot will become unsafe. (There will be drug deals and theft.)
- Property values will decrease.

(See CSAT's Technical Assistance Publication 14, Siting Drug and Alcohol Treatment Programs: Legal Challenges to the NIMBY Syndrome [Weber and Cowie 1995]), for information.)

OT programs do not usually encounter as much community resistance as residential programs; however, potential landlords are often unwilling to lease space to a substance abuse treatment program. The executive should listen attentively to the landlord's concerns and address each directly. The executive should emphasize that clients are not permitted to loiter at the office entrance or smoke in front of the building. References from current landlords also can be helpful. A treatment site should be chosen carefully so that clients feel safe, comfortable, and welcome.

#### Educate potential clients

One way to reach the community is to educate potential clients (and their parents, spouses, and employers) about substance abuse treatment in general and publicize the program and its services. This kind of community outreach can reduce the stigma of substance abuse and present a positive image of recovery. Many people believe that they are not touched by substance abuse. They need basic information about its impact, signs and symptoms, methods of prevention, and treatment options.

#### Other opportunities for outreach

The program should have ongoing relationships with other local groups. Presentations can be given by the program executive, staff, or former clients and might include the following formats:

- An informational event for faith-based institutions, schools, lawyers, physicians and other health care providers, and community organizations (e.g., Lions Clubs, Optimists Clubs) about substance abuse in the area, followed by a question-and-answer period.
- A multisession “understanding addiction” course with slides. These sessions can be promoted to local employers for presentation to their workforces or to EAPs. The presentation can be accompanied by educational slides developed by the program or procured from NIDA (www.nida.nih.gov) or SAMHSA's NCADI (www.ncadi.samhsa.gov).
- A 3- to 4-hour course that combines addiction education with stress management. One program charged $350 each time it presented this material to groups of 30 employees working for a local company.
- Presentations for parent-teacher groups or parents of middle and high school students about substance abuse, including drug paraphernalia and inhalants available in the household. In one community, a program provided each family with a booklet called “A Guide to Winning the Beer Battles.” This guide was designed to help parents respond when their children insisted that “all the kids are doing it.”

### Public Relations—Promoting the Program

#### Promotional materials

A stand-alone brochure with an engaging format is an effective public relations item. It could feature an attention-getting heading, such as “Does someone you know have a drug or alcohol problem?” Often, a checklist of signs that indicate a substance use disorder is an effective public relations tool. Many informative brochures, booklets, and posters are available from SAMHSA's NCADI (www.ncadi.samhsa.gov). One program executive repackages NCADI materials regularly and sends them to local media and community organizations. The name, address, and telephone number of the treatment program should be printed on all promotional materials. The program can coordinate distribution of promotional materials with national events, such as SAMHSA's Recovery Month activities every September.

Program brochures can be illustrated with photographs of the program's facility and list program services and links to other organizations, as well as the name and telephone number of a contact person.

#### Promotional gifts

Creative promotional gifts can be an effective public relations tool. One executive noticed that clients in the driving-while-intoxicated program who smoked tended to have higher blood alcohol levels than nonsmokers. He had matchbooks made with covers advertising the program and distributed them where cigarettes were sold. To food vendors, he gave napkins printed with 10 self-assessment questions and the program's contact information. When staff members gave public presentations, they distributed business cards with the telephone numbers of the presidents of the United States and Russia, the Israeli prime minister, and the Pope, as well as the program's telephone number, local numbers for Alcoholics Anonymous and Narcotics Anonymous, and a suicide hotline. The card was so popular that the program had to print 10,000 at a time.

Post-It^®^ Notes printed with the program's contact information are another useful promotional tool. One program included a pad of notes in each envelope it sent to a referral source.

#### Newspaper and bulletin publicity

The program executive can write columns for and supply news about the program to the local community newspaper, bulletins of faith-based organizations, newsletters of human service agencies, elected officials' letters to constituents, and community listservs. The executive can take information from activity reports to funders or from professional journals in digest form and rewrite it for the general public.

### Television and Radio Access

The executive can create public service announcements for local radio and television stations, appear on interview programs and panel discussions, and produce programming for community-access TV channels. A board member or community leader with expertise can help with these projects.

One way to get free “advertising” is to provide a public service. In one community, a lawyer sponsored a free ride service on New Year's Eve; an IOT program provided the dispatching service. The program was mentioned on the radio, helped the community, and reached people who could benefit from its services.

### Yellow Pages Telephone Directory

Telephone directories often feature free listings in the “Human Services” section. The executive should ensure that the program's service is listed in all relevant sections. If the program has a 24-hour telephone coverage, it can be listed as a 24-hour helpline, which may significantly increase the number of calls. The executive might consider listing the program under “Addiction Services,” which will appear in the beginning of the directory—an advantage that may be more valuable than an expensive advertisement.