# Chapter 1. Introduction

This publication addresses administrative issues in outpatient treatment (OT). A companion volume discusses clinical issues, TIP 47, Substance Abuse: Clinical Issues in Intensive Outpatient Treatment (CSAT 2006b ).

As with all TIPs sponsored by the Center for Substance Abuse Treatment (CSAT), this volume represents the thinking, experience, and work of an expert consensus panel. The consensus panel members are convinced that, in addition to clinical excellence, skilled program administration is vital to the success of an OT program. Today, a program with topnotch clinical therapists can struggle and even fail if it is not well managed. Despite the importance of good management, a review of the literature found almost no research specific to the administration of substance abuse treatment programs. For this reason, this TIP is based less on research than it is on the consensus panel members' many years of collective experience in administering treatment programs.

## Challenges of the Current Treatment Environment

It is the consensus panel's view that OT programs face unprecedented challenges. The health care environment is undergoing extraordinary upheaval. Treatment managers are asked to handle additional demands and requirements with shrinking resources. Good clinical practice increasingly is tied to the need for more sophisticated, more comprehensive, more efficient, and larger program operations. As OT programs have grown in size and variety, their administrative complexity also has grown. To ensure that programs are effective and financially successful, OT administrators need to be skilled in managing the business aspects of treatment. As they develop strategies, plans, and professional relationships for their programs, executives also need to be efficient, creative, innovative, and future oriented, actively looking for new opportunities.

Few OT administrators come to this challenging job with a business or management background. Most are chosen because they have been successful counselors. As clinicians, these new administrators usually had been insulated from the practical aspects of running a program, but management requires a different focus and a different set of skills. Even more important, the skills so crucial for a successful therapist—sensitivity, empathy, insight—do not necessarily make a good administrator. While staying in touch with the work of the program's counselors, an administrator needs to focus on different matters, such as budgets, business opportunities, facilities' operations, staffing, fundraising, and reporting to funders.

Given the career path of many OT program administrators—first counselor, then clinical supervisor, then OT program executive—it is remarkable how well OT programs are managed. Most current OT program managers had to master their new executive responsibilities while on the job with little or no preparation or training. The consensus panel designed this TIP to be a resource for these managers. The turnover rate of program managers in substance abuse treatment is high, with many people assuming new administrative positions. In its survey of more than 400 alcoholism treatment programs, the National Treatment Center Study found that 31 percent of the clinics had experienced some administrative change in the previous year (National Treatment Center Study 1997). It is hoped that this TIP will be useful both for clinicians who are being promoted into executive roles and for experienced administrators. Its suggestions and strategies can help administrators in any substance abuse treatment program.

The OT field today is dynamic, pragmatic, and often chaotic, with an unprecedented number of stressors of all kinds. Managers face many challenges in this difficult environment. This TIP is designed to help administrators manage the following challenges more effectively and creatively:

- Difficult clients. Over the last decade, the consensus panel's experience indicates that clients entering outpatient treatment have demonstrated higher levels of acuteness and more severe mental disorders and sociobehavioral problems than in the past. For example, many persons with a substance use disorder who formerly had been treated in residential programs now are referred directly to outpatient programs. With new approaches, homeless persons have been treated effectively in intensive outpatient programs. OT programs increasingly are treating clients with co-occurring substance use and mental disorders, requiring the level of program and counselor sophistication to rise even though budgets do not keep pace. In addition, the Nation's growing diversity is bringing clients into treatment from many different cultures, each with its own special needs.
- Human resources challenges. Currently, there is a high turnover rate not only of managers but of staff in OT programs. Some studies cite 6-month turnover rates as high as 49 percent among substance abuse treatment staff (Carise et al. 1999, 2000). The scarcity of counselors from diverse backgrounds is particularly acute. Because of the severity of problems among OT clients, programs need to provide both highly skilled therapists and counselor continuity. OT programs report that it is difficult to recruit and retain qualified counselors. With budget constraints, administrators may need to find ways other than salary increases to motivate and reward staff members, such as enhancing staff communication and building a supportive staff environment.
- Extraordinary financial pressures. Limitations on health care funding are placing unprecedented pressure on OT programs. State budgets are contracting dramatically. The behavioral health care system, including substance abuse treatment, is taking the brunt of this financial constriction. OT administrators need to be resourceful and creative and need to engage in long-term strategic planning to keep their programs financially viable. When operating under a variety of payers, an OT administrator needs to be an adroit financial manager.
- A more complex regulatory and legal environment. An OT program can have as many as four different regulatory inspections per year. An administrator needs to make significant shifts in policies and procedures when Federal or State regulations change. For example, the recent Health Insurance Portability and Accountability Act (HIPAA) affects OT programs that use electronic communications. HIPAA requires that administrators understand and meet these new and complex requirements while complying with the Federal confidentiality laws.
- Emergence of the behavioral health system. With the emergence of entities that fund mental disorder and substance abuse treatment separately from other health care, there are efforts to integrate mental disorder and substance abuse treatment (NAADAC 2002). OT administrators may find that it is crucial to set up strategic alliances with other health care providers, especially in mental health care.
- Emphasis on performance outcomes and measurement. The monitoring of program performance and outcomes—combined with a push for evidence-based practices—is the wave of the future. The Federal Government now requires that funding be based on performance outcomes and that States set up performance monitoring systems. States are looking for ways to implement outcomes-based funding. For example, Delaware providers will receive only 75 percent of their previous annual funding if they fail to reach certain performance indicators; if certain outcomes are attained, a provider can receive up to 15 percent above the previous funding level. Administrators need to know how to ratchet up the performance of a treatment program, a challenge requiring skills they may not have learned as clinicians.
- Advances in information technology. Information technology has great potential for improving program efficiency in many areas, such as streamlining counselor recordkeeping, reducing paperwork, coordinating with other providers, and simplifying transactions with payers. With the advantages of computer technology come competitive challenges. Administrators will find that programs are expected to have increasingly sophisticated technology. To be competitive, OT administrators will need to find ways to fund more advanced information technology systems.
- Increased need for marketing and community relationships. Program administrators need to increase their marketing efforts and build relationships in the community. Accrediting bodies now look at a program's relationship with clients and the extent to which the program is integrated into the community. Both public-sector and private providers assign a high priority to marketing and community education.

The challenges are daunting. The information in this TIP will help administrators develop the resources and capacity to meet them. But programs need more than an efficient organizational structure and a motivated staff; they need funds to support their mission. The consensus panel urges administrators to reach out to local residents and businesspeople. Developing strategic alliances and improving community relationships are vital to the success of a program. The needs of OT programs vary from region to region, but in all treatment settings, managing an OT program requires skill and discernment. Beset by multiple challenges, the administrator determines which ones demand immediate attention and which can wait.

## History of Intensive Outpatient Treatment

A brief and selective review of the history of intensive outpatient treatment (IOT) in the United States reveals that the current upsurge in outpatient services is neither new nor guaranteed to endure.

### The Earliest Treatment

Since the earliest days of American history, those addicted to alcohol and drugs have been well represented among patients admitted to American hospitals. As noted by Benjamin Rush, records from Pennsylvania Hospital (the country's first hospital, founded by Benjamin Franklin) state that “the excessive use of ardent spirits” caused “madness” in one-third of the hospital's “maniacs” (Rush [1812] 1962, pp. 32–33). This large proportion is notable because at that time U.S. society strongly preferred to treat secretly individuals who were addicted and to segregate them from other patients. For the first 100 years of the Nation's history, individuals addicted to alcohol, opium, and other substances routinely were treated primarily in secluded residential programs, often referred to as “asylums,” “sanitariums,” or “sober houses” (White 1998).

### 20th-Century Beginnings of Outpatient Treatment

Individuals addicted to alcohol and drugs were first treated on an outpatient basis early in the 20th century. In 1906, the Emmanuel Church in Boston opened a clinic that provided outpatient treatment of disorders involving “weakness or defect of character” (White 1998, p. 100). This clinic sought to integrate psychological, medical, and spiritual approaches into its work with people addicted to alcohol. The Emmanuel Clinic is particularly notable because it was one of the first clinics to employ recovering laypeople as counselors.

Soon after the turn of the century, the Massachusetts Hospital for Dipsomaniacs and Inebriates also established an important outpatient addiction treatment program. By 1916, Massachusetts Hospital had established a statewide network of 29 outpatient sites providing continuity of care following inpatient treatment. Many clinics were located in YMCAs, churches, and hospitals (Tracy 1992). These clinics offered a combination of moral counseling, medical services, and occupational therapy. With the passage of the Volstead Act (the National Prohibition Act) in 1919, this large network of outpatient providers quickly disappeared because the Massachusetts legislature assumed that the new law would end alcoholism permanently.

### 20th-Century Growth of the Outpatient Modality

In 1923, the Yale Laboratory of Applied Physiology (later renamed the Yale Center for Alcohol Studies) was organized to study and treat alcoholism. The Yale Center conducted an ambitious program of research, publication, training, and treatment—the first major practice-research collaborative in America. In 1944, the Yale Center employed psychiatrists and “ex-alcoholics” who worked together and encouraged patient involvement in Alcoholics Anonymous, while providing psychodynamically oriented therapy. By 1957, clinics based on the Yale model were established in 34 States (White 1998). By the late 1950s, OT programs of varying design and intensity had opened across the country, including a number of day treatment programs designed primarily for working people (Fox and Lowe 1968).

By the 1970s, outpatient detoxification (Kolodner 1977) and modern-day treatment programs (Collins et al. 1980; Savitz and Kolodner 1977) became available. Numerous day treatment programs had opened by the 1980s; many offered ambulatory detoxification along with rehabilitation services (Washton and Resnick 1982). These programs were supported with funding provided through county or State agencies and the U.S. Department of Veterans Affairs, although some were supported through private insurance and self-payments. By the mid-1980s, admissions to residential and psychiatric treatment facilities had increased greatly because of the emergence of cocaine and then crack cocaine (Rawson et al. 1983; Washton et al. 1986).

### The Recent Rise of IOT Programs

In the 1980s, in response to the surge in cocaine admissions and its related costs, there was a proliferation of IOT programs geared to treating privately insured, working individuals. Evidence regarding the efficacy of structured and intensive outpatient treatment lent support to the belief that IOT programs could treat many of these clients successfully. Nicholas Cummings, in his presidential address to the American Psychological Association in 1986, predicted the emergence of outpatient treatment as the dominant level of care for the delivery of rehabilitative services (Cummings 1986). By the mid-1990s, public funding sources began turning to IOT programs to treat Medicaid recipients, and IOT managers responded by adapting program designs to accommodate the needs of homeless clients and those with severe co-occurring psychiatric and other biopsychosocial problems.

## Notes About Terminology

Just as the treatment field has yet to settle on a commonly accepted name for itself (e.g., “substance abuse” versus “addiction” versus “substance use disorder” versus “alcohol and drug dependence” versus “chemical dependence”), it is not surprising that the consensus panel has agreed to disagree on a variety of terms and concepts used by the field. Because use of the terms “IOT” and “IOP” (intensive outpatient program) varies by region, for the sake of consistency, the consensus panel agreed to use the term “intensive outpatient treatment” to refer to this level of care instead of the equally acceptable term “intensive outpatient program.” As a consequence, the term “outpatient treatment” also is used. (For a more extensive discussion of the terminology associated with intensive outpatient treatment, see chapter 1 of TIP 47, Substance Abuse: Clinical Issues in Intensive Outpatient Treatment [CSAT 2006b ].)

## Summary of This TIP

The following topics are covered in this volume:

Chapter 2—Management Issues focuses on developing and implementing the structural elements of a successful program, including strategic planning and strategic partnerships, a board of directors, bylaws, and program policy. This chapter also examines the use of strategic relationships to refer clients to programs, to enhance programs' treatment capacity, and to increase programs' visibility. Chapter 2 also addresses the day-to-day management of a treatment program: policies and procedures, staffing, budgeting, sharing new knowledge with staff, and facility management.

Chapter 3—Managing Human Resources examines the recruiting, hiring, and retaining of OT staff members and addresses the appropriate use of a program's human resources. This chapter also discusses the importance of continuing education and training, supervision, and stress reduction for counselors and staff. A client's relationship with a counselor may be the most important factor in treatment, so guidelines are provided for selection, motivation, and retention of skilled counselors.

Chapter 4—Preparing a Program To Treat Diverse Clients discusses how to prepare the staff to be understanding and competent in its treatment of individuals with diverse backgrounds. Eighty-five percent of treatment providers are White, whereas nearly half the clients are from other ethnic groups (Mulvey et al. 2003). Given the dynamic demographic changes the United States has seen in recent years, a culturally competent program will be better prepared to serve more clients. This chapter explains how to perform community, client, and program assessments of cultural competence. Chapter 4 also provides recommendations and an annotated list of resources to assist programs in cultural competence education, assessment, and training.

Chapter 5—Outpatient Treatment Financing Options and Strategies addresses a subject that is crucial in the light of funding cuts, changes in traditional funding streams, and pressure to reduce costs through managed care. Typically, program funding is derived from several sources and may change over time. This chapter discusses the different funding streams, including the complexities of managed care contracting, private sources, and State and Federal funding and how they can be used to support OT services. The chapter also discusses foundations and government grant programs. In addition, chapter 5 examines particular funding sources and the effect they have on the nature and scope of OT programs.

Chapter 6—Performance Improvement and Outcomes Monitoring explores the many facets of measuring treatment performance outcomes—a critical concern as both government and the private sector demand increasing accountability and accreditation. This chapter explores treatment performance indicators such as engagement rate and client satisfaction and the tools used to measure them. Chapter 6 also discusses outcomes measures in today's funding environment, monitoring issues, handling and use of data, and costs and funding of performance monitoring.