# Appendix D—Field Reviewers

- Deion Cash
- Executive Director
- Community Treatment and Correction Center, Inc.
- Canton, Ohio

- Michael Cunningham, Ph.D., CDP
- Clinical Supervisor
- Triumph Treatment Services
- Yakima, Washington

- John G. Daigle, M.A.
- Executive Director
- Florida Alcohol and Drug Abuse Association
- Tallahassee, Florida

- Dennis C. Daley, Ph.D.
- Chief, Addiction Medicine Service
- Associate Professor of Psychiatry
- Western Psychiatric Institute and Clinic
- Pittsburgh, Pennsylvania

- Philip Diaz, M.S.W.
- Chief Executive Office
- Gateway Community Services
- Jacksonville, Florida

- Richard Drandoff, M.A., LPC
- Executive Director
- Change Point, Inc.
- Portland, Oregon

- Marty Estrada
- Case Manager
- General Relief Team
- Ventura Intake and Eligibility Center
- Ventura, California

- Marvin E. Fangman, M.A., LMSW, ACADC
- Program Manager
- First Step: Mercy Recovery Center
- Mercy Medical Center
- Des Moines, Iowa

- Dorothy J. Farr, LSW, LADC
- Clinical Director
- Bucks County Drug and Alcohol Commission
- Warminster, Pennsylvania

- Stephen J. Gumbley, M.A., ACDP II, LCDP
- Project Director
- Discovery House/Smart Management
- Providence, Rhode Island

- James A. Hall, Ph.D., LISW
- Associate Professor
- Department of Pediatrics
- Roy J. and Lucille A. Carver College of Medicine
- University of Iowa
- Iowa City, Iowa

- Sheryl D. Hunter, M.D.
- Massachusetts Mental Health Center
- Boston, Massachusetts

- Jack Kemp, M.S.
- Director of Substance Abuse Services
- Delaware Division of Substance Abuse and Mental Health
- New Castle, Delaware

- Roland C. Lamb
- Manager, Provider Network Administration
- Community Behavioral Health of Philadelphia's Behavioral Health System
- Philadelphia, Pennsylvania

- Thomas E. Lucking, M.A., Ed.S.
- Consultant
- Kalamazoo, Michigan

- Pierluigi Mancini, Ph.D., NCAC II
- Executive Director
- Clinic for Education, Treatment and Prevention of Addiction, Inc.
- (Hispanic Program)
- Atlanta, Georgia

- Michael J. McCann, M.A.
- Associate Director
- Matrix Institute on Addictions
- Los Angeles, California

- Terence McSherry, M.P.H., M.H.A.
- President and Chief Executive Officer
- Northeast Treatment Center
- Philadelphia, Pennsylvania

- Deborah J. Owens, M.S., LPC, CACD, CEAP
- Senior Consultant
- Employee Assistance Programs
- Fort Washington, Pennsylvania

- Harvey A. Siegal, Ph.D.
- Professor and Director
- Center for Interventions, Treatment, and Addictions Research
- Wright State University School of Medicine
- Dayton, Ohio

- Thomas M. Slaven, Ph.D., LPC
- Consulting Associate
- Duke University Medical Center
- Durham, North Carolina

- David Smith, M.D.
- Founder and Medical Director
- Haight-Ashbury Free Clinics
- Medical Director
- California Alcohol and Drug Programs
- San Francisco, California

- Antony P. Stephen, Ph.D., LCSW, RAS
- Executive Director
- New Jersey Asian American Association for Human Services, Inc.
- Elizabeth, New Jersey

- Erik Stone, M.S., CAC III
- Director of Compliance and Quality Improvement
- Signal Behavioral Health Network
- Denver, Colorado

- Kathy J. Stone, M.B.A., LMSW
- Associate Executive Director
- Magellan Behavioral Care of Iowa
- West Des Moines, Iowa

- Tim Williams, M.S.W., LCSW
- Adult Services Director
- Orange, Person and Chatham Area Programs
- Carrboro, North Carolina