# Appendix C—Cultural Competency and Diversity Network Participants

- Faye Belgrave, Ph.D.
- Professor of Psychology
- Virginia Commonwealth University
- Richmond, Virginia

- Thomas P. Beresford, M.D.
- Professor of Psychiatry
- University of Colorado Health Sciences
- Department of Veterans Affairs Medical Center
- Denver, Colorado

- Deion Cash
- Executive Director
- Community Treatment and Correction Center, Inc.
- Canton, Ohio

- Marty Estrada
- Case Manager
- General Relief Team
- East County Intake and Eligibility Center
- Ventura, California

- Michael T. Flaherty, Ph.D.
- Executive Director
- Institute for Research Education and Training in Addictions
- Pittsburgh, Pennsylvania

- Robin C. Halprin, Ph.D.
- Licensed Psychologist
- D.C. Department of Health/CSA
- Washington, D.C.

- Martin Hernandez
- Administrative Assistant
- Ventura County Board of Supervisors, Third District
- Ventura, California

- Alixe McNeil
- Assistant Vice President
- National Council on the Aging
- Washington, D.C.

- Rhoda Olkin, Ph.D.
- Professor of Psychology
- California School of Professional Psychology
- Alameda, California

- David W. Oslin, M.D.
- Assistant Professor
- Geriatric Psychiatry
- University of Pennsylvania
- Philadelphia, Pennsylvania

- Lawrence Schonfeld, Ph.D.
- Professor, Department of Aging and Mental Health
- Louis de la Parte Florida Mental Health Institute
- University of South Florida
- Tampa, Florida

- Antony P. Stephen, Ph.D.
- Executive Director
- Mental Health & Behavioral Sciences
- New Jersey Asian American Association for Human Services, Inc.
- Elizabeth, New Jersey

- Ann Yabusaki, Ph.D.
- Substance Abuse Director
- Coalition for a Drug-Free Hawaii
- Kaneohoe, Hawaii