# Appendix A—Bibliography

Administration for Children and Families. A Guide to Enhancing the Cultural Competence of Runaway and Homeless Youth Programs. Washington, DC: U.S. Department of Health and Human Services, 1994. www.ncfy.com/Guide-to-Enhancing.htm[accessed March 19, 2004].
Administration for Children and Families. Social Services Block Grant Annual Report 2001. Washington, DC: U.S. Department of Health and Human Services, 2001. www.acf.hhs.gov/programs/ocs/ssbg/annrpt/chapter3.html[accessed March 19, 2004].
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition, Text Revision. Washington, DC: American Psychiatric Association, 2000.
Amodeo M, Robb N. Evaluating outcomes in a substance abuse training program for Southeast Asian human service workers: Problems in measuring change cross-culturally. Journal of Drug Education. 1998;28(1):53-63. [pmid: 9567580].
Anderson DW, Bowland BJ, Cartwright WS, Bassin G. Service-level costing of drug abuse treatment. Journal of Substance Abuse Treatment. 1998;15(3):201-211. [pmid: 9633032].
ATTC (Addiction Technology Transfer Center) Network. The Change Book: A Blueprint for Technology Transfer, Second Edition. Kansas City, MO: ATTC National Office, 2004a.
ATTC (Addiction Technology Transfer Center) Network. The Change Book Workbook. Kansas City, MO: ATTC National Office, 2004b.
Bazelon Center for Mental Health Law. Children's Mental Health, Substance Abuse Issues Not Identified. Philadelphia: Bazelon Center for Mental Health Law, May 1, 2003. www.bazelon.org/newsroom/5-1-03epsdt.htm[accessed March 19, 2004].
Beatty, L. Effective therapies for minorities: Meeting the needs of racially and culturally different clients in substance-abuse treatment. Counselor 1(1):37–41, 73, September/October 2000.
Beutler, L.E.; Zetzer, H.; and Yost, E. Tailoring interventions to clients: Effects on engagement and retention. In: Onken, L.S.; Blaine, J.D.; and Boren, J.J.; eds. Beyond the Therapeutic Alliance: Keeping the Drug-Dependent in Treatment. NIDA Research Monograph No. 165. Rockville, MD: U.S. Department of Health and Human Services, 1997, pp. 85–109.
Campbell CI, Alexander JA. Culturally competent treatment practices and ancillary service use in outpatient substance abuse treatment. Journal of Substance Abuse Treatment. 2002;22(3):109-119. [pmid: 12039613].
Carise D, McLellan AT, Gifford LS. Development of a “treatment program” descriptor: The addiction treatment inventory. Substance Use & Misuse. 2000;35(12–14):1797-1818. [pmid: 11138708].
Carise D, McLellan AT, Gifford LS, Kleber HD. Developing a national addiction treatment information system: An introduction to the Drug Evaluation Network System. Journal of Substance Abuse Treatment. 1999;17(12):67-77. [pmid: 10435253].
Center for Mental Health Services. Cultural Competence Standards in Managed Mental Health Services: Four Underserved/Underrepresented Racial/Ethnic Groups. Washington, DC: Substance Abuse and Mental Health Services Administration, 1997.
Center for Substance Abuse Prevention. Following Specific Guidelines Will Help You Assess Cultural Competence in Program Design, Application, and Management. Rockville, MD: Substance Abuse and Mental Services Administration, 1994.
Center for Substance Abuse Prevention. Health Promotion and Substance Abuse Prevention Among American Indian and Alaska Native Communities: Issues in Cultural Competence. Cultural Competence Series 9. DHHS Publication No. (SMA) 99-3440. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001.
Centers for Medicare and Medicaid Services. 2002 Medicaid Managed Care Enrollment Report. Rockville, MD: Substance Abuse and Mental Health Services Administration, n.d. http://www.cms.hhs.gov/MedicaidDataSourcesGenInfo/downloads/mmcer02.pdf[accessed March 19, 2004].
Child Welfare League of America. Cultural Competence Self-Assessment Instrument. Washington, DC: Child Welfare League of America, 1993.
Chinman MJ, Rosenheck MD, Lam JA. Client-case manager racial matching in a program for homeless persons with serious mental illness. Psychiatric Services. 2000;51:1265-1272. [pmid: 11013325].
Coffey, R.M.; Mark, T.; King, E.; Harwood, H.; McKusick, D.; Genuardi, J.; Dilonardo, J.; and Chalk, M. National Estimates of Expenditures for Substance Abuse Treatment, 1997. DHHS Publication No. (SMA) 01-3511. Rockville, MD: Center for Substance Abuse Treatment and Center for Mental Health Services, Substance Abuse and Mental Health Services Administration, February 2001.
Collins GB, Watson EW, Zrimec GL. Hospital day care program for alcoholics. General Hospital Psychiatry. 1980;2:20-22. [pmid: 7380244].
Crits-Christoph P, Siqueland L, Blaine J, Fran A, Luborsky I, Onken LS, Muenz LR, Thase ME, Weiss RD, Gastfriend DR, Woody GE, Barber JP, Butler SF, Daley D, Salloum I, Bishop S, Najavits LM, Lis J, Mercer D, Griffin ML, Moras K, Beck AT. Psychosocial treatments for cocaine dependence: National Institute on Drug Abuse Collaborative Cocaine Treatment Study. Archives of General Psychiatry. 1999;56:493-502. [pmid: 10359461].
Crone EN, Goodman CA, Cocco KM, Harper DC. Substance abuse treatment in persons with special needs. Counselor. 2003;4(1):27-32.
Cross, TL.; Bazron, B.J.; Dennis, K.R.; and Isaacs, M.R. Towards a Culturally Competent System of Care, Vol. 1. Washington, DC: Georgetown University Child Development Center, National Technical Assistance Center for Children's Mental Health, 1989.
CSAT (Center for Substance Abuse and Treatment). Intensive Outpatient Treatment for Alcohol and Other Drug Abuse. Treatment Improvement Protocol (TIP) Series 8. DHHS Publication No. (SMA) 94-2077. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994.
CSAT (Center for Substance Abuse Treatment). Combining Alcohol and Other Drug Abuse Treatment With Diversion for Juveniles in the Justice System. Treatment Improvement Protocol (TIP) Series 21. DHHS Publication No. (SMA) 95-3051. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995.
CSAT (Center for Substance Abuse Treatment). Demystifying Evaluation: A Manual for Evaluating Your Substance Abuse Treatment Program, Vol. 1. DHHS Publication No. (SMA) 99-3341. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1997a, reprinted 1999.
CSAT (Center for Substance Abuse Treatment). A Guide to Substance Abuse Services for Primary Care Clinicians. Treatment Improvement Protocol (TIP) Series 24. DHHS Publication No. (SMA) 97-3139. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1997b.
CSAT (Center for Substance Abuse Treatment). Addiction Counseling Competencies: The Knowledge, Skills, and Attitudes of Professional Practice. Technical Assistance Publication (TAP) Series 21. DHHS Publication No. (SMA) 98-3171. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998a.
CSAT (Center for Substance Abuse Treatment). Comprehensive Case Management for Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series 27. DHHS Publication No. (SMA) 98-3222. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998b.
CSAT (Center for Substance Abuse Treatment). Continuity of Offender Treatment for Substance Use Disorders From Institution to Community. Treatment Improvement Protocol (TIP) Series 30. DHHS Publication No. (SMA) 98-3245. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998c.
CSAT (Center for Substance Abuse Treatment). Substance Use Disorder Treatment for People With Physical and Cognitive Disabilities. Treatment Improvement Protocol (TIP) Series 29. DHHS Publication No. (SMA) 98-3249. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998d.
CSAT (Center for Substance Abuse Treatment). Cultural Issues in Substance Abuse Treatment. DHHS Publication No. (SMA) 99-3278. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999a.
CSAT (Center for Substance Abuse Treatment). Enhancing Motivation for Change in Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series 35. DHHS Publication No. (SMA) 99-3354. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999b.
CSAT (Center for Substance Abuse Treatment). Treatment of Adolescents With Substance Use Disorders. Treatment Improvement Protocol (TIP) Series 32. DHHS Publication No. (SMA) 99-3283. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999c.
CSAT (Center for Substance Abuse Treatment). Substance Abuse Treatment for Persons With Child Abuse and Neglect Issues. Treatment Improvement Protocol (TIP) Series 36. DHHS Publication No. (SMA) 00-3357. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000.
CSAT (Center for Substance Abuse Treatment). Quick Guide for Administrators Based on TIP 27. DHHS Publication No. (SMA) 01-3588. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001.
CSAT (Center for Substance Abuse Treatment). The Confidentiality of Alcohol and Drug Abuse Patient Records Regulation and the HIPAA Privacy Rule: Implications for Alcohol and Substance Abuse Programs. DHHS Publication No. (SMA) 04-3947. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2004. www.hipaa.samhsa.gov/download2/SAMHSAHIPAAComparisonClearedPDFVersion.pdf[accessed April 5, 2005].
CSAT (Center for Substance Abuse Treatment). Substance Abuse Treatment for Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series 44. DHHS Publication No. (SMA) 05-4056. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2005.
CSAT (Center for Substance Abuse Treatment). Addiction Counseling Competencies: The Knowledge, Skills, and Attitudes of Professional Practice—An Update to TAP 21. Technical Assistance Publication (TAP) Series 28. DHHS Publication No. (SMA) 06-4171. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2006a.
CSAT (Center for Substance Abuse Treatment). Substance Abuse: Clinical Issues in Intensive Outpatient Treatment. Treatment Improvement Protocol (TIP) Series 47. DHHS Publication No. (SMA) 06-4182. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2006b.
CSAT (Center for Substance Abuse Treatment). Competencies for Substance Abuse Treatment Clinical Supervisors. Technical Assistance Publication (TAP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, forthcoming a.
CSAT (Center for Substance Abuse Treatment). Improving Cultural Competence in Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, forthcoming b.
Cummings NA. The dismantling of our health system: Strategies for the survival of psychological practice. American Psychologist. 1986;41(4):426-431. [pmid: 3717750].
Daley, D.C., and Marlatt, G.A. Managing Your Drug or Alcohol Problem: Therapist Guide. San Antonio, TX: Harcourt Brace & Co., 1997.
Daley, D.C., and Marlatt, G.A. Managing Your Drug or Alcohol Problem: Client Workbook. San Antonio, TX: Harcourt Brace & Co., 1999.
Deming, W.E. Out of the Crisis. Cambridge, MA: MIT Center for Advanced Education Services, 1986.
De Weert-Van Oene GH, Schippers GM, De Jong CA, Schrijvers GJ. Retention in substance dependence treatment: The relevance of in-treatment factors. Journal of Substance Abuse Treatment. 2001;20(4):253-261. [pmid: 11672639].
Fishman J, Reynolds T, Riedel EA. retrospective investigation of an intensive outpatient substance abuse treatment program. American Journal of Drug and Alcohol Abuse. 1999;25(2):185-196. [pmid: 10395154].
Flynn PM, Porto JV, Rounds-Bryant JL, Kristiansen PL. Costs benefits of methadone treatment in DATOS—Part 1: Discharged versus continuing patients. Journal of Maintenance in the Addictions. 2002;2(12):129-150.
Fox V, Lowe GD. Day-hospital treatment of the alcoholic patient. Quarterly Journal of Studies in Alcohol. 1968;29:634-641.
French, MT.; Bradley, C.J.; and Zarkin, G.A. Drug Abuse Treatment Cost Analysis Program (DATCAP): Cost interview guide for provider sites. Drug Abuse Treatment Module, Version 1. Research Triangle Park, NC: Research Triangle Institute, 1992.
French MT, Dunlap LJ, Zarkin GA, McGeary MA, McLellan AT. A structured instrument for estimating the economic cost of drug abuse treatment: The Drug Abuse Treatment Cost Analysis Program (DATCAP). Journal of Substance Abuse Treatment. 1997;14(4):1-11.
French MT, Roebuck MC, McLellan AT, Sindelar JL. Can the Treatment Services Review be used to estimate the costs of addiction ancillary services?. Journal of Substance Abuse. 2000;12(4):341-361. [pmid: 11452838].
Gallon, S Continuing education and supervision Frontlines: Linking Alcohol Services Research & Practice 6, November 2002.
Gonzalez Castro F, Garfinkle J. Critical issues in the development of culturally relevant substance abuse treatments for specific minority groups. Alcoholism, Clinical and Experimental Research. 2003;27(8):1381-1388.
Gordon, JU, ed. Managing Multiculturalism in Substance Abuse Services. Thousand Oaks, CA: Sage Publications, 1994.
Gropper, R.C. Culture and the Clinical Encounter: An Intercultural Sensitizer for the Health Professions. Yarmouth, ME: Intercultural Press, 1996.
Guthmann D, Blozis SA. Unique issues faced by deaf individuals entering substance abuse treatment and following discharge. American Annals of the Deaf. 2001;146(3):294-304. [pmid: 11523206].
Guthmann D, Sandberg K. Assessing substance abuse problems in deaf and hard of hearing individuals. American Annals of the Deaf. 1998;143(1):14-21. [pmid: 9557328].
Harrison, L The validity of self-reported drug use in survey research: An overview of critique of research methods In: Harrison, L., and Hughes, A., eds. The Validity of Self-Reported Drug Use: Improving the Accuracy of Survey Estimates. NIDA Research Monograph No. 167. Rockville, MD: National Institute on Drug Abuse, 1997, pp. 17–36.
Harwood, H.J.; Kallinis, S.; and Liu, C. The Cost and Components of Substance Abuse Treatment. Rockville, MD: Center for Substance Abuse Treatment, 2001. www.lewin.com/Lewin_Publications/Behavioral_Health/NEDSCostsSATreatment.htm[accessed March 19, 2004].
Health Resources and Services Administration. Cultural Competence Works: Using Cultural Competence To Improve the Quality of Health Care for Diverse Populations and Add Value to Managed Care Arrangements. Washington, DC: U.S. Department of Health and Human Services, 2001. http://minority-health.pitt.edu/archive/00000278/[accessed March 19, 2004].
Ingersoll, K.S.; Wagner, C.C.; and Gharib, S. Motivational Groups for Community Substance Abuse Programs. Richmond, VA: Mid-Atlantic Addiction Technology Transfer Center, 2000.
Institute of Medicine. Improving Health in the Community: A Role for Performance Monitoring. Committee on Using Performance Monitoring To Improve Community Health, Division of Health Promotion and Disease Prevention. Washington, DC: National Academy Press, 1997a.
Institute of Medicine. Managing Managed Care: Quality Improvement in Behavioral Health. Committee on Quality Assurance and Accreditation Guidelines for Managed Behavioral Health Care, Division of Neuroscience and Behavioral Health, Division of Health Care Services. Washington, DC: National Academy Press, 1997b.
Johnson, J.A. Counselor turnover in private facilities. Frontlines: Linking Alcohol Services Research & Practice 5, November 2002.
Joint Commission on Accreditation of Healthcare Organizations (JCAHO). Using Performance Measurement To Improve Outcomes in Behavioral Health Care. Oakbrook Terrace, IL: JCAHO, 1998.
Kaiser Family Foundation and Health Research and Educational Trust. Employer Health Benefits: 2003 Summary of Findings. Washington, DC: Kaiser Family Foundation, 2003. http://www.kff.org/insurance/upload/kaiser-family-foundation-summary-of-findings.pdf[accessed March 19, 2004].
Kluger AN, DeNisi A. The effects of feedback on performance: A historical review, a meta-analysis, and a preliminary feedback intervention theory. Psychological Bulletin. 1996;119(2):254-284.
Knudsen HK, Johnson J.A., Roman P.M. Retaining counseling staff at substance abuse treatment centers: Effects of management practices. Journal of Substance Abuse Treatment. 2003.;24(2):129-135. [pmid: 12745030].
Koenig, L.; Denmead, G.; Nguyen, R.; Harrison, M.; and Harwood, H.The Costs and Benefits of Substance Abuse Treatment: Findings From the National Treatment Improvement Evaluation Study (NTIES). Fairfax, VA: Caliber Associates, 1999. www.icpsr.umich.edu/SAMHDA/NTIES/NTIES-PDF/REPORTS/cost-ben.pdf[accessed March 19, 2004].
Kohls, L.R., and Knight, J.M. Developing Intercultural Awareness: A Cross-Cultural Training Handbook. Yarmouth, ME: Intercultural Press, 1994.
Kolodner, G. Ambulatory detoxification as an introduction to treatment. In: Seixas, F.A., ed. Currents in Alcoholism: Biological, Biochemical and Clinical Studies, Vol. 1. New York: Grune & Stratton, 1977, pp. 311–317.
Kushner, J.N., and Moss, S. Purchasing Managed Care Services for Alcohol and Other Drug Treatment: Essential Elements and Policy Issues. Technical Assistance Publication (TAP) Series 16. Financing Subseries, Vol. III. DHHS Publication No. (SMA) 95-3040. Rockville, MD: Substance Abuse and Mental Health Services Administration, Center for Substance Abuse Treatment, 1995.
Li L, Ford AJ. Illicit drug use by women with disabilities. American Journal of Drug and Alcohol Abuse. 1998;24(3):405-418. [pmid: 9741943].
Mark TL, Buck JA, Dilonardo JD, Coffey RM, Chalk M. Medicaid expenditures on behavioral health care. Psychiatric Services. 2003;54(2):188-194. [pmid: 12556599].
McConnell CR. The health care professional as a manager: Finding the critical balance in a dual role. Health Care Manager. 2002;20(3):1-10. [pmid: 11944811].
McCorry F, Garnick DW, Bartlett J, Cotter F, Chalk M. Developing performance measures for alcohol other drug services in managed care plans. Joint Commission Journal on Quality Improvement. 2000;26(11):633-643. [pmid: 11098426].
McCrone W. A two-year report card on Title I of the Americans with Disabilities Act: Implications for rehabilitation counseling with deaf people. Journal of American Deafness and Rehabilitation Association. 1994;28(2):1-20.
McFadden J. A transcultural perspective: Reaction to CH Patterson's “Multicultural counseling: From diversity to universality. Journal of Counseling and Development. 1996;74:232-235.
McLellan AT, Alterman AI, Cacciola J, Metzger D, O'Brien CP. A new measure of substance abuse treatment: Initial studies of the Treatment Services Review. Journal of Nervous and Mental Disease. 1992;180(2):101-110. a. [pmid: 1737971].
McLellan AT, Kushner H, Metzger D. The fifth edition of the Addiction Severity Index. Journal of Substance Abuse Treatment. 1992;9(3):199-213. b. [pmid: 1334156].
McPhatter AR, Ganaway TL. Beyond the rhetoric: Strategies for implementing culturally effective practice with children, families, and communities. Child Welfare. 2003;82(2):103-124. [pmid: 12699278].
Mecca, AM. Monitoring outcomes: Our new and permanent challenge. Center for Substance Abuse Treatment TIE Communiqué, Fall 1998.
Mee-Lee, D.; Shulman, G.D.; Callahan, J.F.; Fishman, M.; Gastfriend, D.; Hartman, R.; and Hunsicker, R.J., eds. Patient Placement Criteria for the Treatment of Substance-Related Disorders: Second Edition, Revised (PPC-2R). Chevy Chase, MD: American Society of Addiction Medicine, Inc., 2001.
Miller, W., and Rollnick, S. Motivational Interviewing: Preparing People for Change, Second Edition. New York: Guilford Press, 2002.
Mojtabai R, Zivin JG. Effectiveness and cost-effectiveness of four treatment modalities for substance disorders: A propensity score analysis. Health Services Research. 2003;38(1):233-259. [pmid: 12650390]. [pmcid: 1360883].
Monti, P; Kadden, R.; Rohsenow, D.; Cooney, N.; and Abrams, D. Treating Alcohol Dependence: A Coping Skills Training Guide, Second Edition. New York: Guilford Press, 2002.
Moore D, Li L. Prevalence and risk factors of illicit drug use by people with disabilities. American Journal on Addictions. 1998;7(2):93-102. [pmid: 9598213].
Mulvey KP, Hubbard S, Hayashi S. A National Study of the Substance Abuse Treatment Workforce. Journal of Substance Abuse Treatment. 2003;24:51-57. [pmid: 12646330].
NAADAC, The Association for Addiction Professionals NAADAC Calls for Integrated, Seamless System of Care for Brain Disorders. Press release. Alexandria, VA: NAADAC, June 20, 2002. www.naadac.org/pressroom/index.php?PressReleaseID=6[accessed March 19, 2004].
National Institute on Alcohol Abuse and Alcoholism (NIAAA). Cognitive-Behavioral Coping Skills Therapy Manual. Project MATCH Series, Vol. 2. NIH Publication No. 94-3723. Washington, DC: NIAAA, 1994.
National Institute on Alcohol Abuse and Alcoholism (NIAAA). Motivational Enhancement Therapy Manual. Project MATCH Series, Vol. 3. NIH Publication No. 94-3724. Washington, DC: NIAAA, 1995a.
National Institute on Alcohol Abuse and Alcoholism (NIAAA). Twelve Step Facilitation Therapy Manual. Project MATCH Series, Vol. 1. NIH Publication No. 94-3722. Washington, DC: NIAAA, 1995b.
National Treatment Center Study. Six and Twelve Month Follow-up Summary Report. Athens, GA: Institute for Behavioral Research, 1997.
National Treatment Center Study. Summary Report (no. 4): Results of Treatment Center Staff Questionnaires and New Center/Older Center Comparisons. Athens, GA: Institute for Behavioral Research, 1999. http://www.uga.edu/ntcs/reports.htm[accessed March 19, 2004].
National Treatment Center Study. Summary Report (no. 5): Third Wave On-site Results. Athens, GA: Institute for Behavioral Research, 2002. http://www.uga.edu/ntcs/reports.htm[accessed March 19, 2004].
News and Notes. Study finds widespread implementation of managed behavioral health care programs in the public sector. Psychiatric Services 50(2):278, 1999.
Office of Applied Studies, Substance Abuse and Mental Health Services Administration (SAMHSA). The growth of managed care in substance abuse treatment. The DASIS Report. Rockville, MD: SAMHSA, October 19, 2001. http://www.oas.samhsa.gov/2k1/managedcare/managedcare.pdf[accessed March 19, 2004].
Office of Applied Studies, Substance Abuse and Mental Health Services Administration (SAMHSA). National Survey of Substance Abuse Treatment Services (N-SSATS): 2002. Data on Substance Abuse Treatment Facilities. DASIS Series S-19. DHHS Publication No. (SMA) 03-3777. Rockville, MD: SAMHSA, 2003a. http://wwwdasis.samhsa.gov/02nssats/nssats2002report.pdf[accessed March 19, 2004].
Office of Applied Studies, Substance Abuse and Mental Health Services Administration (SAMHSA). Treatment Episode Data Set (TEDS): 1992–2001. National Admissions to Substance Abuse Treatment Services. DASIS Series S-12. DHHS Publication No. (SMA) 02-3778. Rockville, MD: SAMHSA, 2003b. wwwdasis.samhsa.gov/teds01/TEDS2K1Index.htm[accessed March 19, 2004].
Oss, M.E., and Clary, J.H. OPEN MINDS Yearbook of Managed Behavioral Health Market Share in the United States, 1998–1999. Gettysburg, PA: Open Minds, 1999.
Pedersen, P. Handbook for Developing Multicultural Awareness, Third Edition. Alexandria, VA: American Counseling Association, 2000.
Perrin, E.B., and Kostel, J.J., eds. Assessment of Performance Measures for Public Health, Substance Abuse, and Mental Health. National Research Council. Washington, DC: National Academy Press, 1997.
Philips, D.; Leff, S.; Kaniasty, E.; Carter, M.; Paret, M.; Conley, T.; and Sharma, M. Culture, Race, and Ethnicity in Performance Measurement: A Compendium of Resources, Version 1. Washington, DC: Substance Abuse and Mental Health Services Administration, 1999.
Phillips CD, Hubbard RL, Dunteman G, Fountain DL, Czechowicz D, Cooper JR. Measuring program performance in methadone treatment using in-treatment outcomes. Journal of Mental Health Administration. 1995;22(3):214-225. [pmid: 10172390].
Powell, DJ., and Brodsky, A. Clinical Supervision in Alcohol and Drug Abuse Counseling: Principles, Models, Methods, Revised Edition. Hoboken, NJ: Jossey-Bass, 2004.
Prochaska, J.O., and DiClemente, C.C. Toward a comprehensive model of change. In: Miller, W., and Heather, N., eds. Treating Addictive Behaviors: Processes of Change. New York: Plenum Press, 1986, pp. 3–27.
Rawson, R.A.; Mann, A.J.; Tennant, F.S.; and Claybough, D. Efficacy of psychotherapeutic counseling during 21-day ambulatory heroin detoxification. In: Problems of Drug Dependence, 1982: Proceedings of the 44th Annual Scientific Meeting, the Committee on Problems of Drug Dependence, Inc. NIDA Research Monograph No. 43. Rockville, MD: National Institute on Drug Abuse, 1983, pp. 310–314.
Rosenbaum, S.; Teitelbaum, J.; and Mauery, D.R. An Analysis of the Medicaid IMD Exclusion. Washington, DC: George Washington University Center for Health Services Research and Policy, 2002. http://www.gwumc.edu/sphhs/healthpolicy/chsrp/downloads/behavioral_health/reports/IMD%20Report%201202.pdf[accessed March 19, 2004].
Rubenstein, G. The State of State Policy on TANF & Addiction: Findings From the “Survey of State Policies and Practices to Address Alcohol and Drug Problems Among TANF Recipients.” New York: Legal Action Center, 2002. www.lac.org/pubs/gratis/state_of_state.pdf[accessed March 19, 2004].
Rush, B. Medical Inquiries and Observations Upon the Diseases of the Mind. New York: Hafner Publishing, [1812] 1962.
Savitz, S.A., and Kolodner, G.F. Day hospital treatment of alcoholism. In: Masserman, J.H., ed. Current Psychiatric Therapies. New York: Grune & Stratton, 1977, pp. 257–263.
Schmidley, D. The Foreign-Born Population in the United States: March 2002. Current Population Reports P20-539. Washington, DC: U.S. Census Bureau, 2003.
Schoenbaum, M.; Zhang, W.; and Sturm, R. Costs and utilization of substance abuse care in a privately insured population under managed care. Psychiatric Services 49(12):1573–1578, 1998. http://psychservices.psychiatryonline.org/cgi/content/abstract/49/12/1573[accessed March 19, 2004].
Spector, R.E. Cultural Diversity in Health and Illness, Sixth Edition. Upper Saddle River, NJ: Prentice Hall Health, 2003.
Storti, C. Figuring Foreigners Out: A Practical Guide. Yarmouth, ME: Intercultural Press, 1999.
Straussner SL. A Develop your “ethnocultural competence” and improve the quality of your practice. Counselor. 2002;3(6):34-38.
Thomas, R.R., Jr., with Woodruff, M.I. Building a House for Diversity: How a Fable About a Giraffe and an Elephant Offers New Strategies for Today's Workforce. New York: AMACOM, American Management Association, 1999.
Tracy, S. “The Foxborough Experiment: Medicalizing Inebriety at the Massachusetts Hospital for Dipsomaniacs and Inebriates, 1833–1919.” Unpublished doctoral dissertation, University of Pennsylvania, 1992.
U.S. Census Bureau. The Population Profile of the United States: 1999. Current Population Reports P23-205. Washington, DC: U.S. Government Printing Office, 2001. www.census.gov/population/www/pop-profile/profile1999.html[accessed March 19, 2004].
U.S. Department of Health and Human Services. Substance Abuse and Mental Health Services Administration Fiscal Year 2005 Budget. Rockville, MD: Substance Abuse and Mental Health Services Administration, n.d.
Washton, A.M. Editorial: Evolution of intensive outpatient treatment (IOP) as a “legitimate” treatment modality. Journal of Addictive Diseases 16(2):xxi–xxvii, 1997.
Washton, A.M.; Gold, M.S.; and Pottash, A.C. Treatment outcome in cocaine abusers. In: Problems of Drug Dependence, 1985: Proceedings of the 47th Annual Scientific Meeting, the Committee on Problems of Drug Dependence, Inc. NIDA Research Monograph No. 67. Rockville, MD: National Institute on Drug Abuse, 1986, pp. 381–384.
Washton AM, Resnick RB. Outpatient opiate detoxification with clonidine. Journal of Clinical Psychiatry. 1982;43:39-41. [pmid: 7085584].
Weber, EM., and Cowie, R. Siting Drug and Alcohol Treatment Programs: Legal Challenges to the NIMBY Syndrome. Technical Assistance Publication (TAP) Series 14. DHHS Publication No. (SMA) 95-3050. Rockville, MD: Substance Abuse and Mental Health Services Administration, Center for Substance Abuse Treatment, 1995.
Weinrach SG, Thomas KR. Diversity-sensitive counseling today: A postmodern clash of values. Journal of Counseling & Development. 1998;76:115-122.
Weisdorf T, Parran TV Jr, Graham A, Snyder C. Comparison of pregnancy-specific interventions to a traditional treatment program for cocaine-addicted pregnant women. Journal of Substance Abuse Treatment. 1999;16(1):39-45. [pmid: 9888120].
Weissman M, O'Boyle K. Women and addiction: Treatment issues and innovative program models. Source. 2000;10:17-20.
White, WL Slaying the Dragon: The History of Addiction Treatment and Recovery in America. Bloomington, IL: Chestnut Health Systems, 1998.
Wilkerson, D.; Shen, D.; and Duhaime, M. Performance Indicators for Rehabilitation Programs, Version 1.1. Tucson, AZ: Commission on Accreditation of Rehabilitation Facilities, 1998.
Yates, B.T. Analyzing Costs, Procedures, Processes, and Outcomes in Human Services: An Introduction. Thousand Oaks, CA: Sage Publications, 1996.
Yates, B.T. Measuring and Improving Cost, Cost Effectiveness, and Cost-Benefit for Substance Abuse Treatment Programs: A Manual. NIH Publication No. 99-4518. Bethesda, MD: National Institute on Drug Abuse, 1999.
Zarkin GA, Dunlap LJ, Homsi G. The Substance Abuse Services Cost Analysis Program (SASCAP): A new method for estimating drug treatment services costs. Evaluation and Program Planning. 2004;27(1):35-43.