# Appendix F: Field Reviewers

- Cynthia E. Aiken
- Executive Director/Clinical Consultant
- Narcotic Drug Treatment Center, Inc.
- Anchorage, Alaska

- Janet Aiyeku, M.P.A., CASAC
- Associate Director
- Kings County Hospital Center
- Brooklyn, New York

- Norma E. Alexander, CMA
- Board of Directors
- Dora Weiner Foundation
- Staten Island, New York

- Marsha Althoff
- Nursing Supervisor
- Operation PAR
- Clearwater, Florida

- John J. Appeldorn, CAC, LPC, NCC, MAC
- Director of Social Services
- Tadiso, Inc.
- Pittsburgh, Pennsylvania

- G. Dean Austin, M.A.
- Bureau Chief
- Bureau of Substance Abuse Services and Licensure
- Iowa Department of Public Health
- Des Moines, Iowa

- Doug Baker, M.S., CCAS
- North Carolina State Opioid Treatment Authority
- North Carolina Division of Mental Health, Developmental Disabilities, and Substance Abuse Services
- Raleigh, North Carolina

- Cynthia Banfield-Weir, LICSW, BCD
- Clinical Director
- Community Substance Abuse Center
- Chicopee, Massachusetts

- Mac R. Bell
- SAN-Administrator
- Kentucky Division of Substance Abuse Services
- Frankfort, Kentucky

- Bert Bennett, Ph.D.
- Best Practice Team
- North Carolina Division of Mental Health, Developmental Disabilities, and Substance Abuse Services
- Raleigh, North Carolina

- Richard Bilangi, M.S.
- Executive Director
- Connecticut Counseling Centers, Inc.
- Middlebury, Connecticut

- Dona C. Blair, R.N., CHCQM
- Administrator
- The Life Center of Galax
- Galax, Virginia

- Gary Blanchard, M.A., CAC-AD
- Director
- Center for Positive Path Recovery
- Crownsville, Maryland

- Cynthia H. Bolger, R.Ph., FASCP
- Pharmacist Consultant
- Richmond, Virginia

- Jean J.E. Bonhomme, M.D., M.P.H.
- Medical Director
- Alliance Recovery Center
- Decatur, Georgia

- Susan Mayo Bosarge
- State Methadone Authority
- Behavioral Health Services Division
- New Mexico Department of Health
- Santa Fe, New Mexico

- Daniel Brown
- President
- Brown Consulting, Ltd.
- Toledo, Ohio

- Marylee Burns, M.Ed., M.A., CRC
- Assistant Director
- Office of Behavioral Health
- NYC Health and Hospitals Corporation
- New York, New York

- Denise Calcagnino, CSW, CASAC, ADS
- Program Supervisor
- Methadone Maintenance Treatment Program
- Crouse Hospital, Inc.
- Syracuse, New York

- Donald Calsyn, Ph.D.
- Psychologist/Director of Outpatient Services
- Addiction Treatment Center
- Veterans Affairs Puget Sound Health Care System
- Seattle, Washington

- James C. Carleton, M.S.
- Director of Opioid Treatment Services
- CODAC Behavioral Health
- Cranston, Rhode Island

- Matthew Cassidy
- Director of Administration
- Mount Sinai Medical Center's Narcotics Rehabilitation Center
- New York, New York

- Patricia A. Champ, LMHC, LADC
- Clinical Director
- Habit Management Incorporated
- South Yarmouth, Massachusetts

- Steven J. Chen, Ph.D.
- Assistant Director
- Division of Substance Abuse and Mental Health
- Department of Human Services
- Salt Lake City, Utah

- George K. Clarke
- Director
- Southeastern CT Advocates for Recovery Through Medicine
- New London, Connecticut

- Peter Coleman, M.S., CASAC
- Senior Director, Substance Abuse
- NYC Health and Hospitals Corporation
- New York, New York

- Carol Colleran, CAP, ICADC
- National Director
- Older Adult Services
- Hazelden Foundation
- West Palm Beach, Florida

- James P. Connolly, CMA
- Regional Director
- PA-NAMA
- Newtown, Pennsylvania

- Glen J. Cooper, M.A.
- President
- Pennsylvania Association of Methadone Providers
- Allentown, Pennsylvania

- Nancy L. Culver, R.N., CD
- Head Nurse/Unit Manager
- Methadone Program
- Kent County Counseling Services
- Dover, Delaware

- Eugenia Curet, M.S.W.
- Administrative Director
- Adult Services Clinic
- Cornell Medical College
- Department of Public Health
- New York, New York

- Julie D'Ascenzo
- Community Education Coordinator
- PA-NAMA
- Philadelphia, Pennsylvania

- Joy Davidoff, M.P.A.
- Coordinator of Addiction Medicine
- New York State Office of Alcoholism and Substance Abuse Services
- Albany, New York

- Carol Davidson, M.S.W.
- Treatment Director
- Evergreen Treatment Services
- Seattle, Washington

- M. Brooke Dawson, M.S.W., LCSW
- Program Specialist II
- Division of Alcohol and Drug Abuse
- Missouri Department of Mental Health
- Jefferson City, Missouri

- Melissa DeFilippi, M.S.W., LICSW
- Quality Management Manager
- Health and Addictions Research, Inc.
- Boston, Massachusetts

- Peter A. DeMaria, Jr., M.D., FASAM
- Coordinator of Psychiatric Services
- Tuttleman Counseling Services
- Philadelphia, Pennsylvania

- John de Miranda, Ed.M.
- Executive Director
- National Association on Alcohol, Drugs and Disability
- San Mateo, California

- Mairead Desmond, M.A.
- Program Director
- New Directions Treatment Services
- West Reading, Pennsylvania

- Kay M. Doughty
- Director
- Family Centered Substance Abuse Services
- Drug Abuse Comprehensive Coordinating Office, Inc.
- Tampa, Florida

- Sharon R. Dow, M.S.
- Project Director
- Joint Commission on Accreditation of Healthcare Organizations
- Washington, D.C.

- Marilyn Dubin, R.N.
- Nurse Coordinator
- Sinai Hospital Addictions Recovery Program
- Baltimore, Maryland

- Eric Ennis, LCSW, CAC III
- Instructor of Psychiatry/Director of Outpatient Services
- Addiction Research and Treatment Services
- University of Colorado School of Medicine
- Denver, Colorado

- Beth Epstein
- Practice Improvement Director
- TASC, Inc.
- Chicago, Illinois

- Michael Fingerhood, M.D.
- Associate Professor of Medicine
- Johns Hopkins Bayview Medical Center
- Baltimore, Maryland

- Loretta P. Finnegan, M.D.
- Medical Advisor
- Office of Research on Women's Health
- National Institutes of Health
- Bethesda, Maryland

- Michael T. Flaherty, Ph.D.
- Executive Director
- Institute for Research, Education and Training in Addictions
- Northeast Addiction Technology Transfer Center
- Pittsburgh, Pennsylvania

- Beth E. Francisco
- Vice President/Director
- Advocates for Recovery Through Medicine
- Burton, Michigan

- Michael C. Freeman, M.S., LADC, CCS
- Program Director
- Connecticut Counseling Centers, Inc.
- Waterbury, Connecticut

- Michael Galer, D.B.A., M.B.A., M.F.A.
- Chairman of the Graduate School of Business
- University of Phoenix—Greater Boston Campus
- Braintree, Massachusetts

- Devang H. Gandhi, M.D.
- Assistant Professor of Psychiatry
- University of Maryland School of Medicine
- Baltimore, Maryland

- Lynn Gerard
- Quality Improvement Coordinator
- Addiction Research and Treatment
- San Francisco, California

- Karen K. Gilmore-Thomas, LPN
- ADA Liaison/LPN Clinic Administrator
- Substance Abuse Treatment Clinic
- University of Arkansas for Medical Sciences
- Little Rock, Arkansas

- Paolo Giudici, LPCC, LADAC
- Clinical Director
- Ayudantes, Inc.
- Santa Fe, New Mexico

- Alice Gleghorn, Ph.D.
- Project Director
- Community Substance Abuse Services
- San Francisco Department of Public Health
- San Francisco, California

- Janis Gold, LPC, LMFT
- Director
- Outpatient Services
- Alexandria Mental Health, Mental Retardation, and Substance Abuse Services
- Alexandria, Virginia

- Marc N. Gourevitch, M.D., M.P.H.
- Director of Addiction Medicine
- Associate Professor
- Albert Einstein College of Medicine
- Montefiore Medical Center
- Bronx, New York

- Douglas Gourlay, M.D., FRCP, FASAM
- Medical Consultant
- Centre for Addiction and Mental Health
- Toronto, Ontario, Canada

- Diane M. Grieder, M.Ed.
- Owner/Consultant
- AliPar, Inc.
- Suffolk, Virginia

- Therese E. Gruble, M.A., NCC
- Therapist/Project Manager
- Middle Tennessee Treatment Center
- Nashville, Tennessee

- Hildi Hagedorn, Ph.D., LP
- Staff Psychologist
- Minneapolis VA Medical Center
- Minneapolis, Minnesota

- Dana Harlow, LISW, CCDCIII-E
- Manager
- Quality Management Unit
- Ohio Department of Alcohol and Drug Addiction Services
- Columbus, Ohio

- John Haywood, Jr., CSAC, ADS
- Program Manager
- Hampton-Newport News Community Services Board
- Hampton, Virginia

- Laurel Heiser, M.S.W., CSAC
- Assistant Program Director
- Sellati & Co., Inc./Cardinal Group, Inc.
- Richmond, Virginia

- Michael Pierre Henson, LAC
- PIDARC
- Washington, D.C.

- James Herrera, M.A., NCC, LPCC
- Clinical Counselor
- University of New Mexico Hospital
- Albuquerque, New Mexico

- Robert Holden
- Director
- PIDARC
- Washington, D.C.

- Beatrice Huey
- Director
- Program Compliance and Outcome Monitoring
- Arkansas Department of Health, Alcohol and Drug Abuse Prevention
- Little Rock, Arkansas

- Kimberly Johnson
- Director
- Maine Office of Substance Abuse
- Augusta, Maine

- Nora R. Johnson, M.A., CAP
- Program Coordinator
- DACCO Methadone Maintenance Treatment Program
- Tampa, Florida

- Herman Joseph, Ph.D.
- Social Science Research in the Addictions
- Social Research in OASAS
- New York, New York

- Patti Juliana, ACSN
- Associate Executive Director
- Division of Substance Abuse
- Albert Einstein College of Medicine
- Bronx, New York

- David Kalman, Ph.D.
- Assistant Professor
- Department of Psychiatry
- Boston University
- Bedford, Massachusetts

- Linda Kaplan, M.A.
- Executive Director
- Danya Institute/Central East ATTC
- Silver Spring, Maryland

- Jennifer Kasten
- Policy Analyst
- Research Triangle Institute
- Research Triangle Park, North Carolina

- Chris Kelly, M.P.H., M.P.A.
- Advocates for Recovery Through Medicine
- Washington, D.C.

- Van L. King, M.D.
- Associate Professor
- Johns Hopkins University School of Medicine
- Baltimore, Maryland

- Suzanne A. Kinkle, R.N., CARN
- Risk Reduction Coordinator
- Southern New Jersey Perinatal Cooperative
- Registered Nurse
- Kennedy Health System
- Pennsauken, New Jersey

- Steven Kipnis, M.D., FACP, FASAM
- Medical Director
- New York State Office of Alcoholism and Substance Abuse Services
- Orangeburg, New York

- Daniel Kivlahan, Ph.D.
- Director
- Center of Excellence in Substance Abuse Treatment and Education
- VA Puget Sound Health Care System
- Seattle, Washington

- Marc H. Kleinman, Ph.D.
- Regional Administrator
- Methadone Services
- Operation PAR/PAR Clinical Services
- Port Richey, Florida

- Thomas Kosten, M.D.
- Professor of Psychiatry
- Yale University School of Medicine
- New Haven, Connecticut

- Robert C. Lambert, M.A.
- Program Director
- Connecticut Counseling Centers, Inc.
- Norwalk, Connecticut

- John Langrod, Ph.D., CASAC, CSW-R
- Director of Admissions/Evaluation
- Division of Substance Abuse
- Albert Einstein College of Medicine
- Bronx, New York

- Shirley Linzy, R.N., M.S.
- Program Director
- Dr. Miriam & Sheldon G. Adelson Clinic for Drug Abuse Treatment and Research
- Las Vegas, Nevada

- Sheera Lipshitz, M.H.S., CADC
- Director
- Community Support Programs
- Brandywine Counseling
- Wilmington, Delaware

- Howard S. Lotsof, CMA
- President
- Dora Weiner Foundation
- Staten Island, New York

- Thomas Magaraci, M.Ed., M.B.A.
- CEO
- Habit Management
- Boston, Massachusetts

- Terri Martinez
- Director/Consultant
- Addiction Treatment Watchdog
- Platte City, Missouri

- Megan Marx, M.P.A.
- Administrator
- State Controlled Substance
- Alcohol and Drug Abuse Division
- Colorado Department of Human Services
- Denver, Colorado

- Arlene F. Mayotte, R.N., M.S.
- Nurse Manager
- Habit Management
- Fitchburg, Massachusetts

- Elinore F. McCance-Katz, M.D., Ph.D.
- Professor of Psychiatry
- Chair of the Division of Addiction Psychiatry
- Medical College of Virginia
- Virginia Commonwealth University
- Richmond, Virginia

- Brian A. McCarroll, M.S., D.O.
- Medical Director
- Biomed Behavioral Healthcare, Inc.
- Clinton Township, Michigan

- Sarah S. McHugh
- Vice President, Performance Improvement
- Family Guidance Centers, Inc.
- Chicago, Illinois

- Paul McLaughlin, M.A.
- Executive Director
- Hartford Dispensary
- Hartford, Connecticut

- Don McNamee, M.A., LPC, LAODC
- Clinical Supervisor
- Montgomery County Medication Assisted Treatment Program
- Rockville, Maryland

- Ray Miller, M.A., LCADC
- Chief, Treatment Services
- Maryland Alcohol and Drug Abuse Administration
- Catonsville, Maryland

- Carolyn J. Miranda, CMA
- President
- NAMA SOCAL
- Fountain Valley, California

- Richard Moldenhauer, M.S., LADC, ICADC
- State Methadone Authority
- Chemical Health Division
- State of Minnesota
- St. Paul, Minnesota

- Nancy A. Murray, M.A., CAGS, LDCP
- Vice President of Operations
- Discovery House
- Providence, Rhode Island

- Maureen E. Neville
- Certified Methadone (Patient) Advocate
- NAMA
- Haverhill, Massachusetts

- James Nolan, CAS, CPP
- Administrator, Addiction Medicine
- Prison Health Services, Inc.
- Rikers Island
- East Elmhurst, New York

- Jeanne L. Obert, M.F.T., M.S.M.
- Executive Director
- Matrix Institute on Addictions
- Playa Vista, California

- Beth O'Neal, LPC, LMFT
- Clinical Supervisor
- Austin Travis County Mental Health-Mental Retardation
- Austin, Texas

- Carmen Pearman-Arlt, CADAC II
- Director
- Chemical Dependency and Addictions
- Porter Starke Services
- Valparaiso, Indiana

- Luc R. Pelletier, R.N., M.S.N., BC, CPHQ
- Project Director
- Danya International, Inc.
- Silver Spring, Maryland

- Cheryl Petty, R.N., M.S.N., NP
- Coordinator, OSC
- RLR Veterans Affairs Medical Center
- Indianapolis, Indiana

- Mary Planthaber, LPN
- Nursing Manager
- Operation PAR
- Pasco, Pinellas, Manatee, and Lee Counties
- Clearwater, Florida

- Deborah Podus, Ph.D.
- Assistant Research Sociologist
- UCLA Integrated Substance Abuse Programs
- Los Angeles, California

- Deborah J. Powers
- State Methadone Authority
- Department of Health and Family Services
- Madison, Wisconsin

- Michelle R. Rawls, RCAC
- Substance Abuse Counselor
- PIDARC
- Washington, D.C.

- Philip F. Richmond, M.S., LADC
- Associate Director
- Hartford Dispensary
- Hartford, Connecticut

- Kimber P. Richter, Ph.D., M.P.H.
- Assistant Professor
- University of Kansas Medical Center
- Kansas City, Kansas

- Deborah S. Rienhimer, M.S., LCADC
- Treatment Systems Administrator
- Maryland Alcohol and Drug Abuse Administration
- Catonsville, Maryland

- Michael Rizzi
- President/CEO
- CODAC Behavioral Healthcare
- Cranston, Rhode Island

- Elias Robles, Ph.D.
- Research Assistant Professor
- University of Arkansas for Medical Sciences
- Little Rock, Arkansas

- Aaron Rolnick
- Executive Vice President
- Detroit Organizational Needs in Treatment
- Detroit, Michigan

- Andrew J. Saxon, M.D.
- Professor
- Department of Psychiatry and Behavioral Sciences
- University of Washington/VA Puget Sound Healthcare System
- Seattle, Washington

- Brent Scobie, LCSW
- Clinical Supervisor
- The Acadia Hospital
- Bangor, Maine

- Anthony Scro
- Technical Assistance Unit Manager/Board Member
- New York State OASAS/National Alliance of Methadone Advocates
- New York, New York

- Audrey Sellers, M.D.
- Medical Director
- Bay Area Addiction Research and Treatment
- San Francisco, California

- Edward C. Senay, M.D.
- Professor Emeritus, Psychiatry
- University of Chicago
- Naperville, Illinois

- Diane Sevening, Ed.D.
- Assistant Professor
- Alcohol and Drug Abuse Studies Department
- University of South Dakota
- Vermillion, South Dakota

- Stephen Shearer, CPHQ, CCM, CADC, CEAP
- Healthcare Consultant
- Stephen Shearer, Inc.
- Redwood City, California

- Karl G. Sieg, M.D.
- Medical Director of Addiction Psychiatry
- Hampton Roads Clinic
- Hampton, Virginia

- Susan Simon
- CEO/President
- Hepatitis C Association
- Scotch Plains, New Jersey

- Genie Skypek, Ph.D.
- President
- The Skypek Group, Inc.
- Tampa, Florida

- Lisa M. Soderlund
- ACI/OTP Program Supervisor
- CODAC Behavioral Healthcare
- Cranston, Rhode Island

- Jim Soward, CPC, CSAC
- Alcohol and Substance Abuse Program Manager
- Pascua Yaqui Tribe of Arizona
- Tucson, Arizona

- Keith E. Spare
- Program Director
- Rodgers South Opioid Treatment Program/Therapeutic Intervention Center
- Kansas City, Missouri

- Shannon Staggers, BRPS
- Senior Substance Abuse Counselor
- Hartford Dispensary
- Hartford, Connecticut

- Deborah Stephenson, M.D.
- Central Valley Clinic
- San Jose, California

- Eric C. Strain, M.D.
- Professor
- Department of Psychiatry and Behavioral Sciences
- Johns Hopkins University School of Medicine
- Baltimore, Maryland

- William B. Swafford, M.D.
- Medical Director
- Addiction Research and Treatment Services
- Division of Substance Dependence
- University of Colorado Health Sciences Center
- Denver, Colorado

- James Szabo, LICSW
- Manager
- Family Outpatient Services
- Gateway Healthcare
- Pawtucket, Rhode Island

- Charlotte L. Thomas, M.S.W., CACIII
- Retired Addiction Treatment Provider
- Colorado Springs, Colorado

- Elaine Tophia
- Executive Director
- National Opioid Treatment Clinicians Association
- Decatur, Georgia

- Sari Trachtenberg, M.A., CCS, LPC
- Program Coordinator
- Narcotic Addict Rehabilitation Program
- Thomas Jefferson University
- Philadelphia, Pennsylvania

- Ernest J. Vasti, M.D.
- Medical Director
- San Joaquin County
- Office of Substance Abuse
- Stockton, California

- Winifred Verse-Barry, Ph.D., R.N.
- CTP Nursing Coordinator
- Dayton Veterans Affairs Medical Center
- Dayton, Ohio

- Gary Wenner
- Vice President of Methadone and Laboratory Services
- Operation PAR
- Clearwater, Florida

- Carol Wertheimer, Psy.D.
- Director of Clinical Services
- Habit Management
- Boston, Massachusetts

- Melvin H. Wilson
- HIDTA Coordinator
- WB/HIDTA-Maryland Division of Parole and Probation
- Baltimore, Maryland

- Diane Wood, LPN
- LPN/Nurse Supervisor
- Metwork Health Services
- Eldersburg, Maryland

- Johanna Esmus York, M.P.H., CAP
- Program Director, NATC-B
- Operation PAR
- Bradenton, Florida