# Appendix E: Resource Panel

- Nancy Bateman, LCSW-C, CAC
- Senior Staff Associate
- Behavioral Health Care
- National Association of Social Workers
- Washington, D.C.

- Shirley Beckett
- Certification Administrator
- National Association of Alcoholism & Drug Abuse Counselors
- Alexandria, Virginia

- Brent Bowman
- Clinical Director
- Metwork Health Services, Inc.
- Eldersburg, Maryland

- Kurt Brandt, M.D.
- Medical Supervisor
- Alexandria Substance Abuse Services
- Alexandria, Virginia

- Carol Butler
- Program Director
- R.E.A.C.H. Mobile Health Services
- Baltimore, Maryland

- James F. Callahan, D.P.A.
- Executive Vice President
- American Society of Addiction Medicine
- Chevy Chase, Maryland

- Cynthia Cohen, R.N., CS-P
- Clinical Coordinator
- Addiction & Mental Health Center
- Montgomery General Hospital
- Olney, Maryland

- Fred C. Cristofuri, M.D.
- Medical Director
- We Care Methadone Clinic
- Laurel, Maryland

- James Dorsey, M.D.
- Medical Director
- Adult Addiction Services
- Anne Arundel County Department of Health
- Annapolis, Maryland

- Joel A. Egertson
- Drug Policy Advisor
- U.S. Department of Health and Human Services
- Washington, D.C.

- Irene Gainer
- Executive Director
- National TASC
- Washington, D.C.

- Janis Gold
- Director
- Outpatient Services
- Alexandria Mental Health, Mental Retardation, and Substance Abuse Services
- Alexandria, Virginia

- Janice Ford Griffin
- Deputy Director
- Join Together
- Boston University SPH
- Boston, Massachusetts

- Michael G. Hayes, M.D.
- Center for Addiction Medicine
- Baltimore, Maryland

- Vladimire Herard
- Editor
- Substance Abuse Funding News
- Silver Spring, Maryland

- James G. Hill
- Director
- Office of Substance Abuse
- American Psychological Association
- Washington, D.C.

- Hendree Jones, Ph.D.
- Assistant Professor of Psychiatry/Director of Cornerstone/Research Director of Center for Addiction & Pregnancy
- Johns Hopkins University
- Baltimore, Maryland

- Jennifer Kasten
- Policy Analyst
- Research Triangle Institute
- Research Triangle Park, North Carolina

- Chris Kelly, M.P.H., M.P.A.
- Advocates for Recovery Through Medicine
- Washington, D.C.

- Joseph G. Liberto, M.D.
- Clinical Manager
- Substance Abuse Treatment Program
- VA Maryland Health Care System
- American Academy of Addiction Psychiatry
- Baltimore, Maryland

- James J. Manlandro, D.O., FAOAA
- American Osteopathic Academy for Addiction Medicine
- Somerspoint, New Jersey

- David Monosson
- N.A.M.A. Washington Chapter
- N.A.M.A./W.A.M.A.
- Washington, D.C.

- Dennis Scurry, Jr., M.D.
- Chief Medical Officer D.C. Department of Health Addiction Prevention and Recovery Administration
- Washington, D.C.

- Suzan Swanton, LCSW-C
- Clinical Director
- Analyze Research, Inc.
- Baltimore, Maryland

- Susan Tatum
- Therapist Supervisor
- MHMRSA/SA—City of Alexandria
- Alexandria, Virginia

- Annie Umbricht, M.D.
- Medical Director
- SHARP
- Baltimore, Maryland

- Diane Wood, LPN
- LPN/Nursing Supervisor
- Metwork Health Services, Inc.
- Eldersburg, Maryland