# Appendix B: Abbreviations and Acronyms

AA Alcoholics Anonymous

AAS American Association of Suicidology

AATOD American Association for the Treatment of Opioid Dependence (formerly American Methadone Treatment Association [AMTA])

ADA Americans with Disabilities Act of 1990

AD/HD attention deficit/hyperactivity disorder

AMA American Medical Association

APA American Psychiatric Association

APD antisocial personality disorder

ASAM American Society of Addiction Medicine

ASI Addiction Severity Index

ATTC Addiction Technology Transfer Center

AZT zidovudine

CA Cocaine Anonymous

CALDATA California Drug and Alcohol Treatment Assessment

CARF Commission on Accreditation of Rehabilitation Facilities

CBT cognitive behavioral therapy

CDC Centers for Disease Control and Prevention

CFR Code of Federal Regulations

CJS criminal justice system

CNS central nervous system

COPD chronic obstructive pulmonary disease

CPS children's protective services

CRA community reinforcement approach

CSA Controlled Substances Act

CSAT Center for Substance Abuse Treatment

CYP3A4 cytochrome P3A4

CYP450 cytochrome P450

DASIS Drug and Alcohol Services Information System

DATA Drug Abuse Treatment Act of 2000

DAWN Drug Abuse Warning Network

DCP diversion control plan

DEA U.S. Drug Enforcement Administration

DHHS U.S. Department of Health and Human Services

DSM-IV-TR Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition, Text Revision

ECA Epidemiological Catchment Area

ECG electrocardiogram

EEG electroencephalogram

EIA enzyme immunoassay

EMIT Enzyme Multiplied Immunoassay Technique

FDA U.S. Food and Drug Administration

GC/MS gas chromatography/mass spectrometry

HAV hepatitis A virus

HBV hepatitis B virus

HCV hepatitis C virus

HIPAA Health Insurance Portability and Accountability Act of 1996

HIV human immunodeficiency virus

ICD-10 International Statistical Classification of Diseases and Related Health Problems, 10th Edition

IND investigational new drug

IOM Institute of Medicine

JCAHO Joint Commission on the Accreditation of Healthcare Organizations

LAAM levo-alpha acetyl methadol

LGB lesbian, gay, and bisexual

MA Methadone Anonymous

MAT medication-assisted treatment for opioid addiction

MDI Bayley Mental Development Index

MSW medically supervised withdrawal

MTQAS Methadone Treatment Quality Assurance System

NA Narcotics Anonymous

NAPAN National Association for the Prevention of Addiction to Narcotics

NAS neonatal abstinence syndrome

NASADAD National Association of State Alcohol and Drug Abuse Directors

NCADI SAMHSA's National Clearinghouse for Alcohol and Drug Abuse Information

NIDA National Institute on Drug Abuse

NIH National Institutes of Health

NIMBY not in my back yard

NIMH National Institute of Mental Health

OBOT office-based opioid treatment

ONDCP Office of National Drug Control Policy

OTP opioid treatment program

PCR polymerase chain reaction

PEG polyethylene glycol

PPD purified protein derivative

PTSD posttraumatic stress disorder

QSOA Qualified Service Organization Agreement

RIA radioimmunoassay

RNA ribonucleic acid

RTSH Recovery Training and Self-Help

SAMHSA Substance Abuse and Mental Health Services Administration

SAPT Substance Abuse Prevention and Treatment (name of block grant)

SMA State Methadone Authority

SML serum methadone level

SSA Single State Agency

SSRI selective serotonin reuptake inhibitor

STD sexually transmitted disease

SVR sustained virologic response

TB tuberculosis

TC therapeutic community

THC tetra-hydrocannabinol

TIP Treatment Improvement Protocol

TLC thin layer chromatography

TMA transcription mediated amplification

VBRT voucher-based reinforcement therapy