# KAP Expert Panel and Federal Government Participants

- Barry S. Brown, Ph.D.
- Adjunct Professor
- University of North Carolina at Wilmington
- Carolina Beach, North Carolina

- Jacqueline Butler, M.S.W., LISW, LPCC, CCDC III, CJS
- Professor of Clinical Psychiatry
- College of Medicine
- University of Cincinnati
- Cincinnati, Ohio

- Deion Cash
- Executive Director
- Community Treatment and Correction Center, Inc.
- Canton, Ohio

- Debra A. Claymore, M.Ed.Adm.
- Owner/Chief Executive Officer
- WC Consulting, LLC
- Loveland, Colorado

- Carlo C. Di Clemente, Ph.D.
- Chair
- Department of Psychology
- University of Maryland Baltimore County
- Baltimore, Maryland

- Catherine E. Dube, Ed.D.
- Independent Consultant
- Brown University
- Providence, Rhode Island

- Jerry P. Flanzer, D.S.W., LCSW, CAC
- Chief, Services
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- Bethesda, Maryland

- Michael Galer, D.B.A., M.B.A., M.F.A.
- Chairman of the Graduate School of Business
- University of Phoenix—Greater Boston Campus
- Braintree, Massachusetts

- Renata J. Henry, M.Ed.
- Director
- Division of Alcoholism, Drug Abuse, and Mental Health
- Delaware Department of Health and Social Services
- New Castle, Delaware

- Joel Hochberg, M.A.
- President
- Asher & Partners
- Los Angeles, California

- Jack Hollis, Ph.D.
- Associate Director
- Center for Health Research
- Kaiser Permanente
- Portland, Oregon

- Mary Beth Johnson, M.S.W.
- Director
- Addiction Technology Transfer Center
- University of Missouri—Kansas City
- Kansas City, Missouri

- Eduardo Lopez
- Executive Producer
- EVS Communications
- Washington, D.C.

- Holly A. Massett, Ph.D.
- Academy for Educational Development
- Washington, D.C.

- Diane Miller
- Chief
- Scientific Communications Branch
- National Institute on Alcohol Abuse and Alcoholism
- Bethesda, Maryland

- Harry B. Montoya, M.A.
- President/Chief Executive Officer
- Hands Across Cultures
- Espanola, New Mexico

- Richard K. Ries, M.D.
- Director/Professor
- Outpatient Mental Health Services
- Dual Disorder Programs
- Seattle, Washington

- Gloria M. Rodriguez, D.S.W.
- Research Scientist
- Division of Addiction Services
- New Jersey Department of Health and Senior Services
- Trenton, New Jersey

- Everett Rogers, Ph.D.
- Center for Communications Programs
- Johns Hopkins University
- Baltimore, Maryland

- Jean R. Slutsky, P.A., M.S.P.H.
- Senior Health Policy Analyst
- Agency for Healthcare Research & Quality
- Rockville, Maryland

- Nedra Klein Weinreich, M.S.
- President
- Weinreich Communications
- Canoga Park, California

- Clarissa Wittenberg
- Director
- Office of Communications and Public Liaison
- National Institute of Mental Health
- Bethesda, Maryland

## Consulting Members to the KAP Expert Panel

- Paul Purnell, M.A.
- Social Solutions, L.L.C.
- Potomac, Maryland

- Scott Ratzan, M.D., M.P.A., M.A.
- Academy for Educational Development
- Washington, D.C.

- Thomas W. Valente, Ph.D.
- Director, Master of Public Health Program
- Department of Preventive Medicine
- School of Medicine
- University of Southern California
- Alhambra, California

- Patricia A. Wright, Ed.D.
- Independent Consultant
- Baltimore, Maryland