# Consensus Panelists

- Patrick Abbott, M.D.
- Medical Director
- Center on Alcoholism, Substance Abuse, and Addictions
- University of New Mexico
- Albuquerque, New Mexico

- Leslie Amass, Ph.D.
- Principal Investigator
- Friends Research Institute, Inc.
- Los Angeles, California

- Hector D. Barreto, M.D., M.P.H.
- Medical Director
- Center for Drug-Free Living
- Orlando, Florida

- Michael D. Couty
- Director
- Division of Alcohol and Drug Abuse
- Missouri Department of Mental Health
- Jefferson City, Missouri

- Vashti Jude Forbes, R.N., BC., M.S.N., LCDC
- Associate Director
- Substance Abuse and Specialized Services
- Austin Travis County Mental Health and Mental Retardation Center
- Austin, Texas

- Ron Jackson, M.S.W.
- Executive Director
- Evergreen Treatment Services
- Seattle, Washington

- Karol A. Kaltenbach, Ph.D.
- Director
- Maternal Addiction Treatment Education and Research
- Jefferson Medical College
- Thomas Jefferson University
- Philadelphia, Pennsylvania

- Judith Martin, M.D., FASAM
- Medical Director
- 14th Street Clinic & Medical Group, Inc.
- Oakland, California

- Violanda T. Nuñez, M.S.W.
- Executive Director
- Ayudantes, Inc.
- Santa Fe, New Mexico

- J. Thomas Payte, M.D.
- Medical Director
- Drug Dependence Associates
- San Antonio, Texas

- Norma J. Reppucci, R.N.
- Director
- Operations for Eastern MA and NH Community Substance Abuse Centers
- Malden, Massachusetts

- Yong S. Song, Ph.D.
- Assistant Clinical Professor and Program Director
- Opiate Treatment Outpatient Program
- University of California, San Francisco
- San Francisco, California

- Jo L. Sotheran, Ph.D.
- Associate Research Scientist
- Mailman School of Public Health
- Columbia University
- New York, New York

- Trusandra Taylor, M.D.
- Physician Advisor
- Parkside Recovery Methadone Maintenance
- Philadelphia, Pennsylvania