# Editorial Advisory Board

- John D. Crowley
- Crowley Associates
- Elgin, South Carolina

- Herbert D. Kleber, M.D.
- Professor of Psychiatry
- Columbia University College of Physicians & Surgeons
- New York, New York

- Stewart B. Leavitt, Ph.D.
- Leavitt Medical Communications
- Glenview, Illinois

- Jocelyn Sue Woods, M.A.
- President
- National Alliance of Methadone Advocates
- New York, New York

- Joan Zweben, Ph.D.
- Executive Director
- 14th Street Clinic & Medical Group, Inc.
- East Bay Community Recovery Project
- Berkeley, California