# Consensus Panel

## Chair

- Steven L. Batki, M.D.
- Professor and Director of Research
- Department of Psychiatry
- SUNY Upstate Medical University
- Syracuse, New York

## Co-Chairs

- Janice F. Kauffman, R.N., M.P.H., LADC, CAS
- Vice President
- Addiction Treatment Services
- North Charles Foundation, Inc.
- Cambridge, Massachusetts;
- Director
- Addiction Psychiatry Service
- Department of Psychiatry
- Brigham and Women's Hospital
- Boston, Massachusetts; and Assistant Professor of Psychiatry
- Harvard Medical School
- Boston, Massachusetts

- Ira Marion, M.A.
- Executive Director
- Division of Substance Abuse
- Albert Einstein College of Medicine
- Bronx, New York

- Mark W. Parrino, M.P.A.
- President
- American Association for the Treatment of Opioid Dependence
- New York, New York

- George E. Woody, M.D.
- Treatment Research Institute
- University of Pennsylvania/MIRECC Philadelphia VAMC
- Philadelphia, Pennsylvania