# Acknowledgments

Numerous people contributed to the development of this Treatment Improvement Protocol (see pp. xi and xiii as well as Appendixes E and F). This publication was produced by Johnson, Bassin & Shaw, Inc. (JBS), under the Knowledge Application Program (KAP) contract numbers 270-99-7072 and 270-04-7049 with the Substance Abuse and Mental Health Services Administration (SAMHSA), U.S. Department of Health and Human Services (DHHS). Christina Currier served as the Center for Substance Abuse Treatment (CSAT) Government Project Officer, and Andrea Kopstein, Ph.D., M.P.H., served as Deputy Government Project Officer. Robert Lubran, M.S., M.P.A., and Alan Trachtenberg, M.D., served as CSAT technical experts. Lynne McArthur, M.A., A.M.L.S., served as the JBS KAP Executive Project Co-Director. Barbara Fink, R.N., M.P.H., served as the JBS KAP Managing Project Co-Director. Other JBS KAP personnel included Dennis Burke, M.S., M.A., Deputy Director for Product Development; Wendy Caron, Editorial Quality Assurance Manager; Frances Nebesky, M.A., Quality Assurance Editor; Leah Bogdan, Junior Editor; Emily Tinkler, Junior Writer; and Pamela Frazier, Document Production Specialist. Catalina Vallejos Bartlett, M.A., Margaret Brooks, J.D., Jonathan Max Gilbert, M.A., Randi Henderson, and Deborah J. Shuman were writers.