# Appendix N: Field Reviewers

- Calvin Baker
- Addicted Homeless Project
- Program Coordinator
- Division of Addictions and Mental Health
- Prince George's County Health Department
- Forestville, Maryland

- Richard J. Bilangi, M.S.
- Executive Director/President
- Connecticut Counseling Centers, Inc.
- Middlebury, Connecticut

- Dennis L. Bouffard, Ph.D.
- Program Manager
- Connecticut Valley Hospital
- Addiction Services Division
- Middletown, Connecticut

- Kim P. Bowman, M.S.
- Executive Director
- Chester County Department of Drug and Alcohol Services
- West Chester, Pennsylvania

- Patricia Hess Bridgman, M.A., CCDC III-E
- Associate Director
- Ohio Council of Behavioral Healthcare Providers
- Columbus, Ohio

- Barry S. Brown, Ph.D.
- Adjunct Professor
- University of North Carolina at Wilmington
- Carolina Beach, North Carolina

- Vivian B. Brown, Ph.D.
- President/Chief Executive Officer
- Prototypes
- Culver City, California

- Tamara J. Cadet, M.S.W., MPH
- Web Content Manager
- Free to Grow: Head Start Partnerships to Promote Substance-Free Communities
- Columbia University
- Andover, Massachusetts

- Sharon M. Cadiz, Ed.D.
- Senior Director of Special Projects
- Project Return Foundation, Inc.
- New York, New York

- Jerome F.X. Carroll, Ph.D.
- Private Practice
- Brooklyn, New York

- Bruce Carruth, Ph.D., LCSW
- Private Practice
- Laredo, Texas

- Michael Cartwright, Ph.D.
- Executive Director
- Foundations Associates
- Nashville, Tennessee

- Catherine S. Chichester, M.S.N., R.N., CS
- Executive Director
- Co-Occurring Collaborative of Southern Maine
- Portland, Maine

- Carol Coley, M.S., CAPT, USPHS
- Senior Program Management Advisor
- Division of State and Community Assistance
- Systems Improvement Branch
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Margaret A. Cramer, Ph.D.
- Clinical Psychologist/Instructor
- Melrose, Massachusetts

- George De Leon, Ph.D.
- Director
- Center for Therapeutic Community Research
- National Development and Research Institutes, Inc.
- New York, New York

- Janice M. Dyehouse, Ph.D., R.N., M.S.N.
- Professor and Department Head
- College of Nursing
- University of Cincinnati
- Cincinnati, Ohio

- Benjamin M. Eiland, M.A., CATS, EAP
- Director of Substance Abuse Services
- Haight Ashbury Free Clinic
- San Francisco, California

- Dorothy J. Farr
- Clinical Director
- Bucks County Drug and Alcohol Commission, Inc.
- Warminster, Pennsylvania

- Michael I. Fingerhood, M.D., FACP
- Associate Professor
- Department of Medicine
- Center for Chemical Dependence
- School of Medicine
- Johns Hopkins Bayview Medical Center
- Baltimore, Maryland

- Jerry P. Flanzer, D.S.W., LCSW, CAC
- Chief, Services
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- Bethesda, Maryland

- Byron N. Fujita, Ph.D.
- Senior Psychologist
- Clackamas County Mental Health Center
- Oregon City, Oregon

- Gerard Gallucci, M.D., M.H.S.
- Medical Director
- Community Psychiatry Program
- Bayview Medical Center
- Johns Hopkins University
- Baltimore, Maryland

- Mary Gillespie, Psy.D., CASAC
- Psychologist
- Saratoga Springs, New York

- Karen Scott Griffin, M.S.
- Director of Administration
- Gaudenzia, Inc.
- Norristown, Pennsylvania

- Valerie A. Gruber, Ph.D., M.P.H.
- Assistant Clinical Professor
- University of California, San Francisco
- San Francisco, California

- Nancy Handmaker, Ph.D.
- Professor
- Department of Psychology
- The University of New Mexico
- Albuquerque, New Mexico

- Edward Hendrickson, LMFT, MAC
- Clinical Supervisor
- Arlington County MHSASD
- Arlington, Virginia

- David Hodgins, Ph.D.
- Professor
- Department of Psychology
- University of Calgary
- Calgary, Canada

- Kimberly A. Johnson
- Director
- Maine Office of Substance Abuse
- Augusta Mental Health Complex
- Augusta, Maine

- Edith Jungblut
- Public Health Advisor
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- George A. Kanuck
- Public Health Analyst
- Co-Occurring and Homeless Branch
- Division of State and Community Assistance
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Michael W. Kirby, Jr., Ph.D.
- Chief Executive Officer
- Arapahoe House, Inc.
- Thornton, Colorado

- Daniel R. Kivlahan, Ph.D.
- Director
- VA Center of Excellence in Substance Abuse Treatment and Education
- VA Puget Sound Health Care System
- Seattle, Washington

- Ting-Fun May Lai, M.S.W., CSW, CASAC
- Director
- Chinatown Alcoholism Services
- New York, New York

- Linda Lantrip, D.O., R.N.
- Medical Director
- Central Oklahoma Community
- Mental Health Center
- Norman, Oklahoma

- Robert M. Long, M.S., LCDC, LADC
- Director of Substance Abuse and Dual Diagnosis Services
- Kennebee Valley Mental Health Center
- Augusta, Maine

- Russell P. MacPherson, Ph.D., CAP, CAPP, CCP, CDVC, DAC
- President
- RPM Addiction Prevention Training
- Sanford, Florida

- Philip R. Magaletta, Ph.D.
- Clinical Training Coordinator
- Federal Bureau of Prisons
- Washington, DC

- G. Alan Marlatt, Ph.D.
- Professor of Psychology
- Director, The Addictive Behaviors Research Center
- University of Washington
- Seattle, Washington

- Julia W. Maxwell, LICSW, CAS
- Branch Manager
- Department of Mental Health/Community Services/
- Mental Health and Addiction Services
- St. Elizabeth's Campus
- Washington, DC

- Frank A. McCorry, Ph.D.
- Director
- Clinical Services Unit
- N.Y.S. Office of Alcoholism and Substance Abuse Services
- New York, New York

- Gregory J. McHugo, Ph.D.
- Research Associate Professor
- Dartmouth Medical School
- NH-Dartmouth Psychiatric Research Center
- Lebanon, New Hampshire

- David Mee-Lee, M.D., FASAM
- DML Training and Consulting
- Davis, California

- Kenneth Minkoff, M.D.
- Medical Director
- Choate Health Management
- Woburn, Massachusetts

- Theresa Moyers, Ph.D.
- Assistant Research Professor
- Department of Psychology
- University of New Mexico
- Albuquerque, New Mexico

- Ethan Nebelkopf, Ph.D., MFCC
- Clinic Director
- Family and Child Guidance Center
- Native American Health Center
- Oakland, California

- Gwen M. Olitsky, M.S.
- Chief Executive Officer
- The Self-Help Institute for Training and Therapy
- Lansdale, Pennsylvania

- Thomas A. Peltz, M.Ed., LMHC, CAS
- Therapist
- Private Practice
- Beverly Farms, Massachusetts

- Stephanie W. Perry, M.D.
- Assistant Commissioner of Health
- Bureau of Alcohol and Drug Abuse Services
- Tennessee Department of Health
- Nashville, Tennessee

- Lawrence D. Rickards, Ph.D.
- Co-Occurring Disorders Program Manager
- Homeless Programs Branch
- Center for Mental Health Services
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Jeffery L. Rohacek, M.S., CASAC
- Psychologist II
- McPike Addiction Treatment Center
- Utica, New York

- Edwin M. Rubin, Psy.D.
- Psychologist
- Aurora Behavioral Health Services
- Aurora Health Care
- Milwaukee, Wisconsin

- Theresa Rubin-Ortiz, LCSW
- Clinical Director
- Bonita House, Inc.
- Oakland, California

- Margaret M. Salinger, M.S.N., R.N., CARN
- Unit/Program Manager
- Coatesville VA Medical Center
- Coatesville, Pennsylvania

- Steven V. Sawicki
- Assistant Program Director
- Center for Human Development
- Connecticut Outreach-West
- Waterbury, Connecticut

- Anna M. Scheyett, M.S.W., LCSW, CASWCM
- Clinical Assistant Professor
- School of Social Work
- University of North Carolina
- Chapel Hill, North Carolina

- Marilyn S. Schmal, M.A., CSAC
- Mental Health Therapist II
- Arlington County Mental Health
- Substance Abuse Services
- Arlington, Virginia

- Darren C. Skinner, Ph.D., LSW, CAC
- Director
- Gaudenzia, Inc.
- Gaudenzia House West Chester
- West Chester, Pennsylvania

- David E. Smith, M.D.
- Founder and President
- Haight Ashbury Free Clinics, Inc.
- San Francisco, California

- Antony P. Stephen, Ph.D.
- Executive Director
- Mental Health and Behavioral Sciences
- New Jersey Asian American Association for Human Services, Inc.
- Elizabeth, New Jersey

- Norm Suchar
- Program and Policy Analyst
- National Alliance to End Homelessness
- Washington, DC

- Richard T. Suchinsky, M.D.
- Associate Chief for Addictive Disorders and Psychiatric Rehabilitation
- Mental Health and Behavioral Science Services
- Department of Veterans Affairs
- Washington, DC

- Kimberly N. Sutton, Ph.D.
- Director/Associate Professor of Psychiatry
- Cork Institute on Alcohol and Other Drug Abuse
- Morehouse School of Medicine
- Atlanta, Georgia

- Mary Lynn Ulrey, M.S., ARNP
- Chief Operating Officer
- Operation PAR, Inc.
- Pinellas Park, Florida

- Robert Walker, M.S.W., LCSW
- Assistant Professor
- Center on Drug and Alcohol Research
- University of Kentucky
- Lexington, Kentucky

- Verner Stuart Westerberg, Ph.D.
- President
- Addiction Services Research
- Albuquerque, New Mexico

- Aline G. Wommack, R.N., M.S.
- Deputy Director
- Division of Substance Abuse and Addiction Medicine
- UCSF Deputy Department of Psychiatry
- San Francisco, California

- Ann S. Yabusaki, Ph.D.
- Director
- Coalition for a Drug-Free Hawaii
- Honolulu, Hawaii

- Mariko Yamada, LCSW
- Clinical Supervisor
- Asian American Drug Abuse Program Inc.
- Gardena, California

- Debby Young
- Windsor, California

- Joan E. Zweben, Ph.D.
- Executive Director
- East Bay Community Recovery Project
- University of California
- Berkley, California