# Appendix M: Cultural Competency and Diversity Network Participants

- Raymond Daw, M.A.
- Executive Director
- Na'nizhoozhi Center, Inc.
- Gallup, New Mexico
- Disabilities Work Group

- Michael I. Fingerhood, M.D., FACP
- Associate Professor
- Department of Medicine
- Center for Chemical Dependence
- School of Medicine
- Johns Hopkins Bayview Medical Center
- Baltimore, Maryland
- Aging Work Group

- Ting-Fun May Lai, M.S.W., CSW, CASAC
- Director
- Chinatown Alcoholism Center
- Hamilton-Madison House
- New York, New York
- Asian and Pacific Islanders Work Group

- Antony P. Stephen, Ph.D.
- Executive Director
- Mental Health & Behavioral Sciences
- New Jersey Asian American Association for Human Services, Inc.
- Elizabeth, New Jersey
- Asian and Pacific Islanders Workgroup

- Richard T. Suchinsky, M.D.
- Associate Chief for Addictive Disorders and Psychiatric Rehabilitation
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, DC
- Disabilities Work Group

- Ann S. Yabusaki, Ph.D.
- Director
- Coalition for a Drug-Free Hawaii
- Honolulu, Hawaii
- Asian and Pacific Islanders Work Group