# Appendix L: Resource Panel

- Robert E. Anderson
- Director
- Research and Program Applications
- National Association of State Alcohol and Drug Abuse Directors
- Washington, DC

- Nancy Bateman, LCSW-C, CAC
- Senior Staff Associate
- Division of Professional Development and Advocacy
- National Association of Social Workers
- Washington, DC

- James F. Callahan, D.P.A.
- Executive Vice President
- American Society of Addiction Medicine
- Chevy Chase, Maryland

- Frank Canizales, M.S.W.
- Management Analyst, Alcohol Program
- Division of Clinical and Preventive Services
- Indian Health Service
- Rockville, Maryland

- Cathi Coridan, M.A.
- Senior Director for Substance Abuse
- Programs and Policy
- National Mental Health Association
- Alexandria, Virginia

- Jennifer Fiedelholtz
- Public Health Analyst
- Office of Policy and Program Coordination
- Substance Abuse and Mental Health Services
- Administration
- Rockville, Maryland

- Ingrid D. Goldstrom, M.Sc.
- Center for Mental Health Services
- Rockville, Maryland

- Lynne M. Haverkos, M.D., M.P.H.
- Program Director
- Behavioral Pediatrics and Health Promotion Research Program
- National Institute of Child Health and Human Development
- Bethesda, Maryland

- Edward Hendrickson, LMFT, MAC
- Clinical Supervisor
- Arlington County MHSASD
- Arlington, Virginia

- Kevin D. Hennessy, Ph.D.
- Senior Health Policy Analyst
- Office of the Assistant Secretary for Planning and Evaluation
- Department of Health and Human Services
- Washington, DC

- James (Gil) Hill, Ph.D.
- Director
- Office of Rural Health and Substance Abuse
- American Psychological Association
- Washington, DC

- Hendree E. Jones, Ph.D.
- Assistant Professor
- Department of Psychiatry and Behavioral Sciences
- Johns Hopkins University Center
- Baltimore, Maryland

- Diane M. Langhorst
- Clinical Supervisor
- Substance Abuse Services
- Henrico Area Mental Health and Retardation Services
- Richmond, Virginia

- Tom Leibfried, M.P.A.
- Vice President of Government Relations
- National Council for Community Behavioral Healthcare
- Rockville, Maryland

- James J. Manlandro, D.O.
- Director
- Family Addiction Treatment Services, Inc.
- Dennisville, New Jersey

- Julia W. Maxwell, L.I.C.S.W., C.A.S.
- Branch Director
- Mental Health Addiction and Services Branch
- Commission on Mental Health Services
- District of Columbia
- Washington, DC

- William F. Northey, Jr., Ph.D.
- Research Specialist
- American Association for Marriage and Family Therapy
- Alexandria, Virginia

- Fred C. Osher, M.D.
- Director
- Center for Behavioral Health, Justice and Public Policy
- University of Maryland
- Jessup, Maryland

- Terry C. Pellmar, Ph.D.
- Director
- Board on Neuroscience and Behavioral Health
- Institute of Medicine
- Washington, DC

- Ernst Quimby, Ph.D.
- Associate Professor
- Department of Sociology and Anthropology
- Howard University
- Washington, DC

- Susan E. Salasin
- Director
- Mental Health and Criminal Justice
- Program
- Center for Mental Health Services
- Rockville, Maryland

- Laurel L. Stine, J.D., M.A.
- Director of Federal Relations
- Bazelon Center for Mental Health Law
- Washington, DC

- Richard T. Suchinsky, M.D.
- Associate Director for Addictive Disorders and Psychiatric Rehabilitation
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, DC

- Jan Towers, Ph.D., CRNP
- Director
- Health Policy
- American Academy of Nurse Practitioners
- Washington, DC

- Steve Wing
- Senior Advisor for Drug Policy
- Office of Policy and Program Coordination
- Substance Abuse and Mental Health
- Services Administration
- Rockville, Maryland