# Appendix J: Dual Recovery Mutual Self-Help Programs and Other Resources for Consumers and Providers

## Dual Recovery 12-Step Fellowships

### Double Trouble in Recovery

The organization provides 12 steps that are based on a traditional adaptation of the original 12 steps. For example, the identified problem in step one is changed to co-occurring disorders, and the population to be assisted is changed in step 12 accordingly. The organization provides a format for meetings that are chaired by members of the fellowship.

- Contact information
- Double Trouble in Recovery
- c/o Mental Health Empowerment Project
- 271 Central Avenue
- Albany, NY 12209
- (518) 434-1393
- www.doubletroubleinrecovery.org

### Dual Diagnosis Anonymous

The organization provides a hybrid approach that developed 5 steps in conjunction with the traditional 12 steps. The five steps differ from those of other dual recovery groups in underscoring the potential need for medical management, clinical interventions, and therapies. The organization provides a meeting format that is used by fellow members who chair the meetings.

- Contact information
- Dual Diagnosis Anonymous
- 320 North E. Street, Suite 207
- San Bernardino, CA 92401
- (909) 888-9282

### Dual Disorders Anonymous

The organization provides 12 steps that are based on a traditional adaptation of the original 12 steps. For example, the identified problem in step one is changed to co-occurring disorders, and the population to be assisted is changed in step 12 accordingly. The organization provides a format for meetings that are chaired by members of the fellowship.

- Contact information
- Dual Disorders Anonymous
- P.O. Box 681264
- Schaumburg, IL 60168
- (847) 781-1553

### Dual Recovery Anonymous

The organization provides 12 steps that are an adapted and expanded version of the traditional 12 steps. The expanded approach changes the identified problem to co-occurring disorders, and the population to be assisted is changed accordingly. It also retains most of the traditional language while modifying certain terms in an effort to meet the needs of mental health consumers. In addition, it incorporates affirmations into three of the 12 steps. The organization provides a meeting format that is used by fellow members who chair the meetings.

- Contact information
- Dual Recovery Anonymous World Services, Inc.
- P.O. Box 8107
- Prairie Village, KS 66208
- (877) 833-2332 (toll-free)
- E-mail: draws@draonline.org
- www.draonline.org

## Supported Mutual Help for Dual Recovery

### Dual Diagnosis Recovery Network (DDRN)

The DDRN is a program of Foundations Associates that derives part of its funding from the Tennessee Department of Mental Health and Developmental Disabilities, as well as the Tennessee Department of Health, Bureau of Alcohol and Drug Abuse Services. DDRN provides dual recovery mutual help information in all areas of the services that are offered; education and training through community programs, inservice training, workshops, State, regional, and national conferences; advocacy and coalition building through networking and coordinating a statewide task force that engages chemical dependency and mental health professionals, consumers, and family members; provides information through the Dual Network quarterly journal and the resource and information clearinghouse.

- Contact information
- Dual Diagnosis Recovery Network (DDRN)
- 220 Venture Circle
- Nashville, TN 37228
- (888) 869-9230
- www.dualdiagnosis.org

### Support Together for Emotional/Mental Serenity and Sobriety (STEMSS)

STEMSS is a psychoeducational group intervention. The model has been developed to train facilitators to initiate, implement, and maintain support groups for consumers. The six steps of the program and the support groups are intended to complement participation in traditional 12-Step programs.

- Contact information
- Michael G. Bricker, Executive Director
- STEMSS Institute and Bricker Clinic
- 140 E. Dekora Street
- Saukville, WI 53080
- (414) 268-0899

## Other Resources for Consumers and Providers

### Consumer Organization and Networking Technical Assistance Center (CONTAC)

CONTAC distributes a list of names and contacts for resources and information on substance addictions, co-occurring disorders, services, and mutual help support. CONTAC also offers the Leadership Academy, a training program that is designed to help consumers learn how to engage in and develop consumer services. Recently, a training component focusing on substance abuse/dependence was developed and incorporated into the program.

- Contact information
- Consumer Organization and Networking Technical Assistance Center (CONTAC)
- 1036 Quarrier Street, Suite 208A
- Charleston, WV 25891
- (304) 346-9992 or (888) 825-8324
- www.contac.org

### National Council on Alcoholism and Drug Dependence (NCADD)

NCADD has a nationwide network of nearly 100 affiliates. These affiliates provide information and referrals to local services, including counseling and treatment. NCADD also offers a variety of publications and resources.

- Contact information
- NCADD National Office
- 20 Exchange Place, Suite 2902
- New York, NY 10005
- (212) 269-7797
- Fax: (212) 269-7510
- E-mail: national@ncadd.org
- www.ncadd.org

### National Empowerment Center

The National Empowerment Center has prepared an information packet, which includes a series of published articles, newspaper articles, and a listing of organizations and Federal agencies that provide information, resources, and technical assistance related to substance abuse and dependence, co-occurring disorders, services, and mutual help support.

- Contact information
- National Empowerment Center
- 599 Canal Street
- Lawrence, MA 01840
- (800) 769-3728
- www.power2u.org

### National Mental Health Association

The National Mental Health Association has expanded its mission to encompass substance abuse/addictions and co-occurring disorders. The organization continues to develop resources, documents, and publications. A designated section on the organization's Web site is dedicated to co-occurring disorders.

- Contact information
- National Mental Health Association
- 1021 Prince Street
- Alexandria, VA 22314-2971
- (800) 969-6642
- TTY: (800) 433-5959
- www.nmha.org

### National Mental Health Consumers' Mutual Help Clearinghouse

The organization has developed and offers a resource kit, which provides the names and contacts for resources and information on substance addictions, co-occurring disorders, services, and mutual help support.

- Contact information
- National Mental Health Consumers' Self-Help Clearinghouse
- 1211 Chestnut Street, Suite 1207
- Philadelphia, PA 19107
- (800) 553-4KEY
- www.mhselfhelp.org