# Appendix I: Selected Sources of Training

## Sources of Training on Addiction Disorders

### Addiction Technology Transfer Centers (ATTCs)

Check with your local ATTC. Course offerings vary.

- www.nattc.org
- For curricula, lectures, videos, and printed training materials available through ATTCs, see www.nattc.org/resPubs.html
- For information on distance training offered by ATTCs and other providers, see www.addictionED.org

### Hazelden Institute

Hazelden offers training opportunities at many levels and locations.

The Graduate School of Addiction Studies offers both a Master of Arts in Addiction Studies and individualized programs. A Chemical Dependency Counselor Certificate program is available for those with less formal training. Contact the Graduate School at (888) 257-7800, ext. 4175 for more information.

www.hazelden.org

The Hazelden Distance Learning Center for Addiction Studies provides opportunities for home-based study. Courses may be taken via the Web or using traditional print materials. Contact the Distance Learning Center at (800) 328-9000 for more information.

www.dlcas.com

### National Association for Alcohol and Drug Abuse Counselors (NAADAC)

The NAADAC Web site includes lists of approved education providers, distance learning opportunities, and post-secondary programs. Home study materials are also available through NAADAC. Contact: (800) 548-0497.

www.naadac.org

### National Clearinghouse for Alcohol and Drug Information (NCADI)

The Substance Abuse and Mental Health Services Administration's (SAMHSA's) NCADI distributes materials developed by SAMHSA's Center for Substance Abuse Prevention and Center for Substance Abuse Treatment, along with several other agencies. Contact NCADI at (800) 729-6686 for more information.

- www.ncadi.samhsa.gov

### National Institute on Alcohol Abuse and Alcoholism (NIAAA)

Project Matching Alcoholism Treatments to Client Heterogeneity (MATCH) manuals are the result of the collaborative efforts of the Project MATCH investigators and are used as guides by the therapists in the trial. They are presented to the alcohol research community as standardized, well-documented intervention tools for alcoholism treatment research. The manuals address 12-Step facilitation, motivational enhancement, and cognitive-behavioral treatments.

- To access Project MATCH materials, see www.niaaa.nih.gov/publications/match.htm for an order form or write to:

National Institute on Alcohol Abuse and Alcoholism

Publications Distribution Center

P.O. Box 10686

Rockville, MD 20849-0686

### National Institute on Drug Abuse (NIDA)

NIDA publishes a wide variety of treatment-related materials, including a three-volume set of therapy manuals for cocaine addiction. Contact: (301) 443-1124.

www.nida.nih.gov

### National Development and Research Institutes, Inc. (NDRI)

NDRI offers an extensive training program of 75 courses in substance abuse and HIV/AIDS, consultation, and technical assistance for program development and implementation. Contact: (212) 846-4566.

- www.ndri.org

### Other University-Based Training

A number of universities offer training. For example, the Division on Addictions at Harvard Medical School offers a fellowship in addictions and other training for counselors, MSWs, and other clinicians.

### Rutgers Center for Alcohol Studies

The Center for Alcohol Studies offers two types of programs through its Education and Training Division. Both the School of Alcohol and Drug Studies and the Institute of Alcohol and Drug Studies offer weeklong programs throughout the summer months for interested professionals and laypersons. During the academic year, professionals may choose 1-day courses from the Continuing Professional Education Seminars. Contact the Center's Education and Training Division at (732) 445-4317 for more information.

www.rci.rutgers.edu/~cas2/

### State Certifying Boards for Chemical Dependency Counseling

A list of individual State boards is available through NAADAC. Contact: (800) 548-0497 or visit www.naadac.org. Another list is available through the International Certification and Reciprocity Consortium. Contact: (919) 572-6823.

www.icrcaoda.org/icrclist.htm

## Sources of Training on Mental Health

### American Counseling Association

Home study courses, learning institutes, and onsite training. Contact: (703) 823-9800.

www.counseling.org

### American Psychological Association

Office of Continuing Professional Education. Home study and other approved courses, including some co-occurring disorder specific offerings. Contact: (202) 336-5991.

- www.apa.org/ce/

### American Psychiatric Association

Office of Continuing Medical Education. Gives CME credits for review and exam based on the Association's annual meeting. Ask for a listing of other conferences and courses available for CME credits. Contact: (202) 682-6179.

www.psych.org

### National Mental Health Information Center (NMHIC)

This is a service of SAMHSA's Center for Mental Health Services. NMHIC distributes materials developed by the Center for Mental Health Services and other agencies. Several training manuals are among the publications offered. Contact NMHIC at (800) 789-2647 for more information.

- www.mentalhealth.samhsa.gov

### National Institute of Mental Health (NIMH)

NIMH provides a variety of manuals and research reports, including texts on anxiety disorders and depression. Contact: (301) 443-4513.

www.nimh.nih.gov

## Sources of Training on Co-Occurring Disorders

### Addiction Technology Transfer Centers (ATTCs)

Check with your local ATTC. Course offerings vary.

www.nattc.org/map.html

- For distance training offered by ATTCs and other providers, see www.addictionED.org
- For curricula, lectures, videos, and printed training materials: www.nattc.org/resPubs.html (search for co-occurring disorders)

### Formal Continuing Education COD Curricula

Several examples follow:

#### Dual Recovery Project

Houston Community College, University of Houston, Harris County MHMRA, Houston, Texas. Contact: (713) 970-7000.

trustin@pol.net

#### Integrated Program Development and Clinical Interventions

Foundations Associates and the Dual Diagnosis Recovery Network in Nashville, TN provide specialized training on implementation and financing of integrated program models and integrated clinical interventions. Contact: (888) 869-9230.

- www.dualdiagnosis.org; mcartwright@dualdiagnosis.org

#### MISA Curriculum

Seven modules, Behavioral Healthcare Resource Program, University of North Carolina, School of Social Work. Contact: (919) 962-1225.

ssw@unc.edu

#### National Development and Research Institutes

NDRI has a COD Curriculum with 10 modules targeting the generalist. Contact: (646) 638-2497.

www.ndri.org

#### Washington State Institute for Mental Health Research and Training

The institute has extensive training materials as well as training videotapes on COD. Contact: (253) 756-2741.

#### Miscellaneous Training

A variety of training opportunities are listed by Kathleen Sciacca at

http://users.erols.com/ksciacca/upcom.htm

#### State-Sponsored Training

Many States have developed model curricula.

## Listservs and Discussion Groups on Co-Occurring Disorders

The following is a selection of listservs and discussion groups dealing specifically with the topic of co-occurring disorders. These online communication networks offer members the opportunity to post suggestions or questions to a large number of people at the same time. Listservs differ in that they are generally geared more toward professionals and are more closely monitored. Discussion groups are usually open to anyone, and may not be closely monitored. Submissions to listservs are distributed to all members, so before submitting a query or a comment to an entire listserv group, you may wish to monitor the discussions.

### CataList—The Official Catalog of Listserv Lists

CataList, a general resource, is a catalog of more than 55,000 listserv lists. It allows users to browse listserv lists, search by keyword for mailing lists of interest, and obtain information about listserv host Web sites. CataList contains information only about public lists; confidential lists and lists of purely local interest are not in the searchable database.

- www.lsoft.com/lists/listref.html

### Co-Occurring Dialogues

As an expansion of services to the CSAT Treatment Improvement Exchange on the Web (www.treatment.org), the Division of State and Community Assistance has established Co-Occurring Dialogues, a listserv focusing on issues related to dual diagnosis. Subscription to the Co-Occurring Dialogues discussion list (dualdx@treatment.org) is free and unrestricted. Just send an e-mail to dualdx@treatment.org stating a desire to subscribe. A description of membership, purpose, and utilization will follow your subscription.

This discussion list belongs to the field. Membership is open, but the list is moderated, and CSAT reserves the right to remove any member who the agency feels is not interacting in a professional manner. Co-Occurring Dialogues is offered as a means of communication, idea sharing, brainstorming, sharing of exciting publications and opportunities, etc. It is an open vehicle for communication between and among researchers, educators, treatment agencies, the recovery community, treatment providers, and all levels of government.

www.treatment.org/Topics/DualDialogues.html

#### Dual Diagnosis Bulletin Board

This subdivision of the Dual Diagnosis Listserv is a more general discussion area. Visitors can review postings on the bulletin board by clicking on headings of interest, and/or submit information for posting to the bulletin board. This area is open to anyone, consumers as well as professionals, and is not moderated.

cgibin.erols.com/ksciacca/cgi-bin/bb/

#### Dual Diagnosis Listserv

This listserv is operated by Dr. Kathleen Sciacca, Founding Executive Director of Sciacca Comprehensive Service Development for Mental Illness, Drug Addiction and Alcoholism (MIDAA), located in New York City. The listserv is an extension of the Dual Diagnosis Web site (users.erols.com/ksciacca), and is reserved for persons who are credentialed in the mental health and substance abuse fields and have an interest in the theory, practice, treatment, systemic change, and program implementation for dual/multiple disorders in various combinations. A resume or curriculum vitae must be submitted in order to subscribe. Membership is determined at the discretion of the list manager. Once credential information is received, members will receive a welcome message informing them of acceptance to the list and instructions on how to post to the forum.

users.erols.com/ksciacca/ddl.htm

#### Dual Diagnosis Pages: Colleagues List

The Colleagues List is a division of The Dual Diagnosis Pages (www.toad.net/~arcturus/dd/ddhome.htm), a general resource Web site for co-occurring addiction and personality disorders. The Colleagues List allows professionals to act as mutually supporting resources. Mental health and substance abuse treatment professionals can post a description of themselves and their qualifications/background so that practitioners with common interests, issues, or questions can get in touch with each other.

www.toad.net/~arcturus/dd/colleag.htm

#### MIDAS: Discussion Group

MIDAS is a member of the Dual Disorder Web Ring, and offers a Discussion Group through Yahoo.com. MIDAS is an Australian site provided by the South Western Sydney Area Health Service, but it offers links to programs and resources around the world. There are no special conditions for joining the Discussion Group, and new members are joining all the time. However, the description given on the home page freely acknowledges that the group gets active only from time to time, sometimes slowing down for months.

www.swsahs.nsw.gov.au/areaser/Midas/default.asp