# Appendix B: Acronyms

AA | Alcoholics Anonymous
AAAP | American Academy of Addiction Psychiatry
AACP | American Association of Community Psychiatrists
ACA | Adult Children of Alcoholics
ACT | Assertive Community Treatment
AD/HD | attention deficit/hyperactivity disorder
ADM | Alcohol, Drug Abuse or Mental Disorders
AHRQ | Agency for Healthcare Research and Quality (formerly AHCPR)
AIDS | acquired immunodeficiency syndrome
AOD | alcohol and other drugs
AOS | addiction only services
APA | American Psychological Association; American Psychiatric Association
APD | antisocial personality disorder
APPI | American Psychiatric Publishing, Inc.
ASAM | American Society of Addiction Medicine
ASI | Addiction Severity Index
ATTC | Addiction Technology Transfer Center
AUDIT | Alcohol Use Disorders Identification Test
AUS | Alcohol Use Scale
BAI | Beck Anxiety Inventory
BDI | Beck Depression Inventory
BED | Binge-eating disorder
BPD | borderline personality disorder
BSI-18 | Brief Symptom Inventory-18
CA | Cocaine Anonymous
CAMI | chemically abusing mentally ill, or chemically addicted and mentally ill
CBT | cognitive—behavioral therapy
CCISC | Comprehensive Continuous Integrated System of Care
CINA | Clinical Institute Narcotic Assessment
CIWA-Ar | Clinical Institute Withdrawal Assessment
CM | Contingency Management
CMHS | Center for Mental Health Services (SAMHSA)
COD | co-occurring disorders (in this TIP, specifically co-occurring substance abuse and one or more mental health disorders)
CONTAC | Consumer Organization and Networking Technical Assistance Center
CQI | Continuous Quality Improvement
CSAP | Center for Substance Abuse Prevention (SAMHSA); Corrections Substance Abuse Program
CSAT | Center for Substance Abuse Treatment (SAMHSA)
CTU | Crisis Triage Unit
DALI | Dartmouth Assessment of Lifestyle Inventory
DAST | Drug Abuse Screening Test
DATOS | Drug Abuse Treatment Outcome Studies
DBT | Dialectical Behavior Therapy
DDC | dual diagnosis capable
DDE | dual diagnosis enhanced
DDRN | Dual Diagnosis Recovery Network
DID | dissociative identity disorder, formerly known as multiple personality disorder
DIS | Diagnostic Interview Schedule
DSM-IV | Diagnostic and Statistical Manual of Mental Disorders, 4th Edition
DTR | Double Trouble in Recovery
DUI | driving under the influence
DUS | Drug Use Scale
EAP | employee assistance program
ECA | Epidemiological Catchment Area
ER | emergency room
FY | fiscal year
GA | Gamblers Anonymous
GAD | general anxiety disorder
GAIN | Global Appraisal of Individual Needs
HIP | HIV Integration Project
HIPAA | Health Insurance Portability and Accountability Act
HIV | human immunodeficiency virus
ICM | Intensive Case Management
ICOPSD | individuals with co-occurring psychiatric and substance disorders
IOM | Institute of Medicine
LOCUS | Level of Care Utilization System
MAST | Michigan Alcoholism Screen Test
MATCH | Matching Alcoholism Treatment to Client Heterogeneity
MDDA | Manic Depressive and Depressive Association
MET | Motivational Enhancement Techniques
MFIR | Men's Forensic Intensive Recovery
MHSF-III | Mental Health Screening Form-III
MI | Motivational Interviewing
MICA | mentally ill chemically addicted or affected, mentally ill chemical abusing, or mentally ill chemical abuser
MICD | mentally ill chemically dependent
MIDAS | Mental Illness Drug and Alcohol Screening
MINI | Mini-International Neuropsychiatric Interview
MISA | mentally ill substance abuser
MISU | mentally ill substance using
MMPI | Minnesota Multiphasic Personality Inventory
MTC | Modified Therapeutic Community
NA | Narcotics Anonymous
NAADAC | National Association of Alcoholism and Drug Abuse Counselors
NAC | National Advisory Council
NAMI | National Alliance for the Mentally Ill
NASADAD | National Association of State Alcohol and Drug Abuse Directors
NASMHPD | National Association of State Mental Health Program Directors
NCADI | National Clearinghouse for Alcohol and Drug Information
NCI | Na'nizhoozi Center, Inc.
NCS | National Comorbidity Study
NIAAA | National Institute on Alcohol Abuse and Alcoholism
NIDA | National Institute on Drug Abuse
NIH | National Institutes of Health
NIMH | National Institute of Mental Health
NLAES | National Longitudinal Alcohol Epidemiologic Study
NMHA | National Mental Health Association
NRC | National Research Council
NTIES | National Treatment Improvement Evaluation Study
OCD | obsessive-compulsive disorder
ONDCP | Office of National Drug Control Policy
PCP | phencyclidine
PD | personality disorder
PG | pathological gambling
PIC | Practice Improvement Collaboratives
PPC | patient placement criteria
PRISM | Psychiatric Research Interview for Substance and Mental Disorders
PTSD | posttraumatic stress disorder
RPT | Relapse Prevention Therapy
SADAP | State Alcohol and Drug Abuse Profiles
SAMHSA | Substance Abuse and Mental Health Services Administration
SAMI | substance abusing mentally ill
SAMM | Substance Abuse Management Module
SCID | Structured Clinical Interview for Diagnosis
SDS | Symptom Distress Scale
SMI | severely mentally ill
SOGS | South Oaks Gambling Screen
SPMI | serious and persistent mental illness
SSI | Simple Screening Instrument for AOD Abuse
SSRI | selective serotonin reuptake inhibitor (a type of antidepressant)
STD | sexually transmitted disease
STEMSS | Support Together for Emotional/Mental Serenity and Sobriety
STP | Short-Term Program
TC | therapeutic community
TIP | Treatment Improvement Protocol
TREM | Trauma Recovery and Empowerment Model
UFDS | Uniform Facility Data Set
URICA | University of Rhode Island Change Assessment Scale
WFIR | Women's Forensic Intensive Recovery