# Appendix A: Bibliography

Abraham SF, Beaumont PJ. (1982). How patients describe bulimia or binge eating. Psychological Medicine.
Abueg, F.R., and Fairbank, J.A. Behavioral treatment of posttraumatic stress disorder and co-occurring substance abuse. In: Saigh, P.A., ed. Posttraumatic Stress Disorder: A Behavioral Approach to Assessment and Treatment. Boston: Allyn and Bacon, 1992. pp. 111–144.
Adams JB, Wacher A. (1968). Specific changes in the glycoprotein components of seromucoid in pregnancy. Clinica Chimica Acta: International Journal of Clinical Chemistry.
Addington J, Duchak V. (1997). Reasons for substance use in schizophrenia. Acta Psychiatrica Scandinavica.
Addington J, el-Guebaly N, Campbell W, Hodgins DC, Addington D. (1998). Smoking cessation treatment for patients with schizophrenia. American Journal of Psychiatry.
Addington J, el-Guebaly N, Duchak V, Hodgins D. (1999). Using measures of readiness to change in individuals with schizophrenia. American Journal of Drug and Alcohol Abuse.
Alcoholics Anonymous World Services. The AA Member—Medications and Other Drugs: A Report from a Group of Physicians in AA. New York: Alcoholics Anonymous World Services, 1984.
Alexander MJ. (1996). Women with co-occurring addictive and mental disorders: An emerging profile of vulnerability. American Journal of Orthopsychiatry.
Allen, J.P., and Wilson, V.B. Assessing Alcohol Problems: A Guide for Clinicians and Researchers, 2d ed. Bethesda, MD: National Institute on Alcohol Abuse and Alcoholism, 2003.
American Academy of Pediatrics, Committee on Drugs. (2001). The transfer of drugs and other chemicals into human milk. Pediatrics.
American Association of Community Psychiatrists. LOCUS—Level of Care Utilization System, Psychiatric and Addiction Services. Adult Version. 2000a. www.wpic.pitt.edu/aacp/finds/LOCUS2000.pdf[Accessed January 25, 2002].
American Association of Community Psychiatrists. Principles for the Care and Treatment of Persons with Co-Occurring Psychiatric and Substance Disorders. 2000b. www.comm.psych.pitt.edu/finds/dualdx.html[Accessed October 19, 2004].
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 3d ed. Washington, DC: American Psychiatric Association, 1980.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 3d ed. Revised. Washington, DC: American Psychiatric Association, 1987.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 4th ed. Washington, DC: American Psychiatric Association, 1994.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 4th Text Revision ed. Washington, DC: American Psychiatric Association, 2000.
American Society of Addiction Medicine. Patient Placement Criteria for the Treatment of Substance-Related Disorders: ASAM PPC-2R. 2d Revised ed. Chevy Chase, MD: American Society of Addiction Medicine, 2001.
American Society of Addiction Medicine. Principles of Addiction Medicine, 3d ed. Graham, A.W., Schultz, T.K., Mayo-Smith, M.F., Ries, R.K., and Wilford, B.B., eds. Chevy Chase, MD: American Society of Addiction Medicine, 2003.
Amodeo M, Robb N, Peou S, Tran H. (1997). Alcohol and other drug problems among Southeast Asians: Patterns of use and approaches to assessment and intervention. Alcoholism Treatment Quarterly.
Anderson, A.J. Therapeutic program models for mentally ill chemical abusers. International Journal of Psychosocial Rehabilitation 1(1):21–33, 1997. www.psychosocial.com/dualdx/rehabpub.html[Accessed March 18, 2002].
Anderson CM, Teicher MH, Pocari A, Renshaw PF. (2002). Abnormal T2 relaxation time in the cerebellar vermis of adults sexually abused in childhood: Potential role of the vermis in stress-enhanced risk for drug abuse. Psychoneuroendocrinology.
Anthony, J.C. and Echeagaray-Wagner, F. Epidemiologic analysis of alcohol and tobacco use: Patterns of co-occurring consumption and dependence in the United States. Alcohol Research & Health. 2000. http://www.niaaa.nih.gov/publications/arh24-4/201-208.pdf[Accessed November 19, 2004].
Anthony WA. (1996). Integrating psychiatric rehabilitation into managed care. Psychiatric Rehabilitation Journal.
Arapahoe House. Connections: A dyadic case management, integrated program for dually diagnosed individuals. In: Center for Mental Health Services and Center for Substance Abuse Treatment, Insights and Inroads: Project Highlights of the CMHS and CSAT Collaborative Demonstration Program for Homeless Individuals. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000.
Argus Community. Program Description. New York: Argus Community, 2002.
Association of Problem Gambling Service Administrators. APGSA Quick Reference Guide. Lincoln, NE: Association of Problem Gambling Service Administrators, 2002. www.apgsa.org/memberservices.htm[Accessed November 6, 2002].
Babor, T.F., de la Fuente, J.R., Saunders, J., and Grant, M. AUDIT. The Alcohol Use Disorders Identification Test. Guidelines for Use in Primary Health Care. Geneva, Switzerland: World Health Organization, 1992.
Bachrach LL. (1992). What we know about homelessness among mentally ill persons: An analytic review and commentary. Hospital and Community Psychiatry.
Bailey L, Maxwell S, Brandabur MM. (1997). Substance abuse as a risk factor for tardive dyskinesia: A retrospective analysis of 1,027 patients. Psychopharmacology Bulletin.
Baker, F. Coordination of Alcohol, Drug Abuse, and Mental Health Services. Technical Assistance Publication (TAP) Series 4. DHHS Publication No. (SMA) 00-3360. Rockville, MD: Center for Substance Abuse Treatment, 1991.
Ball SA. (1998). Manualized treatment for substance abusers with personality disorders: Dual Focus Schema Therapy. Addictive Behaviors.
Ball SA, Young JE. (2000). Dual focus schema therapy for personality disorders and substance dependence: Case study results. Cognitive and Behavioral Practice.
Ballenger JC, Davidson JRT, Lecrubier Y, Nutt DJ, Marshall RD, Nemeroff CB, Shalev AY, Yehuda R. (2004). Consensus statement update on posttraumatic stress disorder from the international consensus group on depression and anxiety. Journal of Clinical Psychiatry.
Barbee JG, Clark PD, Crapanzano MS, Heintz GC, Kehoe CE. (1989). Alcohol and substance abuse among schizophrenic patients presenting to an emergency psychiatric service. Journal of Nervous and Mental Disease.
Barley, W.D. Behavioral and cognitive treatment of criminal and delinquent behavior. In: Reid, W.H., Dorr, D., Walker, J.I., and Bonner, J.W., III, eds. Unmasking the Psychopath: Antisocial Personality and Related Syndromes. New York: W.W. Norton, 1986. pp. 159–190.
Barlow, D.H. Anxiety and Its Disorders: The Nature and Treatment of Anxiety and Panic. 2d ed. New York: Guilford Press, 2002.
Bartels SJ, Drake RE, Wallach MA. (1995). Long-term course of substance use disorders among patients with severe mental illness. Psychiatric Services.
Bassuk EL, Lamb HR. (1986). Homelessness and the implementation of deinstitutionalization. New Directions for Mental Health Services.
Beary MD, Lacey JH, Merry J. (1986). Alcoholism and eating disorders in women of fertile age. British Journal of Addiction.
Beck AT, Epstein N, Brown G, Steer RA. (1988). An inventory for measuring clinical anxiety: Psychometric properties. Journal of Consulting and Clinical Psychology.
Beck, A.T., and Steer, R.A. Manual for the Beck Depression Inventory. San Antonio, TX: The Psychological Corporation, 1987.
Beck, A.T., Steer, R.A., and Brown, G.K. Beck Depression Inventory—II Manual. San Antonio, TX: The Psychological Corporation, 1996.
Becker DR, Bond GR, McCarthy D, Thompson D, Xie H, McHugo GJ, Drake RE. (2001). Converting day treatment centers to supported employment programs in Rhode Island. Psychiatric Services.
Behavior Data Systems. Gambler Addiction Index: Orientation and Training Manual. Phoenix, AZ: Behavior Data Systems, 2000.
Belcher JR. (1988). Relationship between the deinstitutionalization model, psychiatric disability, and homelessness. Health and Social Work.
Benjamin, L.S. Interpersonal Diagnosis and Treatment of Personality Disorders. New York: Guilford Press, 1993.
Berenson, D., and Schrier, E.W. Current family treatment approaches. In: Graham, A.W., Schultz, T.K., and Wilford, B.B., eds. Principles of Addiction Medicine. 2d ed. Chevy Chase, MD: American Society of Addiction Medicine, 1998. pp. 1115–1125.
Bergh C, Ejderhamn J, Sodersten P. (2003). What is the evidence basis for existing treatments of eating disorders?. Current Opinion in Pediatrics.
Bergler, E. The Psychology of Gambling. New York: Hill and Wang, 1957.
Bernstein, N. A plan to end city homelessness in 10 years. New York Times. June 13, 2002. p. B6.
Beumont PJ, George GC, Smart DE. (1976). “Dieters” and “vomiters and purgers” in anorexia nervosa. Psychological Medicine.
Blanchard EB, Jones-Alexander J, Buckley TC, Forneris CA. (1996). Psychometric properties of the PTSD Checklist (PCL). Behaviour Research & Therapy.
Blankertz L, McKay C, Robinson S. (1998). Work as a rehabilitative tool for individuals with dual diagnoses. Journal of Vocational Rehabilitation.
Blaszczynski, A. Overcoming Pathological Gambling: A Self-Help Guide Using Cognitive-Behavioral Techniques. London: Robinson Publishing, 1998.
Blume AW, Davis JM, Schmaling KB. (1999). Neurocognitive dysfunction in dually-diagnosed patients: A potential roadblock to motivating behavior change. Journal of Psychoactive Drugs.
Blume, S.B. Women and alcohol: Issues in social policy. In: Wilsnack, R.W., and Wilsnack, S.C., eds. Gender and Alcohol: Individual and Social Perspectives. New Brunswick, NJ: Rutgers Center of Alcohol Studies, 1997. pp. 462–489.
Blumenthal SJ. (1988). Suicide: A guide to risk factors, assessment, and treatment of suicidal patients. Medical Clinics of North America.
Bo-Linn GW, Santa Ana CA, Morawski SG, Fordtran JS. (1983). Purging and calorie absorption in bulimic patients and normal women. Annals of Internal Medicine.
Bonin, E., Brehove, T., Kline, S., Misgen, M., Post, P., Strehlow, A.J., and Yungman, J. Adapting Your Practice: General Recommendations for the Care of Homeless Patients. Nashville, TN: Health Care for the Homeless Clinicians' Network, National Health Care for the Homeless Council, Inc., 2004.
Brady KT, Dansky BS, Back SE, Foa EB, Carroll KM. (2001). Exposure therapy in the treatment of PTSD among cocaine-dependent individuals: Preliminary findings. Journal of Substance Abuse Treatment.
Brady KT, Killeen TK, Brewerton T, Lucerini S. (2000). Comorbidity of psychiatric disorders and posttraumatic stress disorder. Journal of Clinical Psychiatry.
Brady KT, Killeen T, Saladin ME, Dansky B, Becker S. (1994). Comorbid substance abuse and posttraumatic stress disorder. American Journal on Addictions.
Brady KT, Sonne SC, Roberts JM. (1995). Sertraline treatment of comorbid posttraumatic stress disorder and alcohol dependence. Journal of Clinical Psychiatry.
Braun DL, Sunday SR, Halmi KA. (1994). Psychiatric comorbidity in patients with eating disorders. Psychological Medicine.
Breiter HC, Aharon I, Kahneman D, Dale A, Shizgal P. (2001). Functional imaging of neural responses to expectancy and experience of monetary gains and losses. Neuron.
Breslau N, Davis GC, Andreski P, Peterson EL, Schultz LR. (1997). Sex differences in posttraumatic stress disorder. Archives of General Psychiatry.
Breslau N, Davis GC, Schultz LR. (2003). Posttraumatic stress disorder and the incidence of nicotine, alcohol, and other drug disorders in persons who have experienced trauma. Archives of General Psychiatry.
Breslau N, Novak SP, Kessler RC. (2004a). Daily smoking and the subsequent onset of psychiatric disorders. Psychological Medicine.
Breslau N, Novak SP, Kessler RC. (2004b). Psychiatric disorders and stages of smoking. Biological Psychiatry.
Broner, N., Borum, R., Gawley, K. Criminal justice diversion of individuals with co-occurring mental illness and substance use disorders: An overview. In: Landsberg, G., Rock, M., Berg, L., and Smiley, A., eds. Serving Mentally Ill Offenders and Their Victims: Challenges and Opportunities for Social Workers and Other Mental Health Professionals. New York: Springer Publishing, 2002.
Brook, R.C., and Whitehead, P.C. Drug-Free Therapeutic Community: An Evaluation. New York: Human Sciences Press, 1980.
Broome KM, Flynn PM, Simpson DD. (1999). Psychiatric comorbidity measures as predictors of retention in drug abuse treatment programs. Health Services Research.
Brooner RK, King VL, Kidorf M, Schmidt CW, Bigelow GE. (1997). Psychiatric and substance use comorbidity among treatment-seeking opioid abusers. Archives of General Psychiatry.
Brower KJ, Aldrich MS, Robinson EA. (2001). Insomnia, self-medication and relapse to alcoholism. American Journal of Psychiatry.
Brown BS. (1998). Making a difference—Is journal publication enough?. Journal of Substance Abuse Treatment.
Brown, B.S. From research to practice—The bridge is out and the water's rising. In: Levy, J.A., Stephens, R.C., and McBride, D.C., eds. Emergent Issues in the Field of Drug Abuse. Advances in Medical Sociology: Vol. 7. Stamford, CT: JAI Press, 2000. pp. 345–365.
Brown BS, Flynn PM. (2002). The federal role in drug abuse technology transfer: A history and perspective. Journal of Substance Abuse Treatment.
Brown PJ, Recupero PR, Stout R. (1995). PTSD substance abuse comorbidity and treatment utilization. Addictive Behaviors.
Brown PJ, Stout RL, Gannon-Rowley J. (1998). Substance use disorder-PTSD comorbidity: Patients' perceptions of symptom interplay and treatment issues. Journal of Substance Abuse Treatment.
Brown PJ, Wolfe J. (1994). Substance abuse and post-traumatic stress disorder comorbidity. Drug and Alcohol Dependence.
Brown RI. (1987a). Dropouts and continuers in Gamblers Anonymous: III. Some possible specific reasons for dropout. Journal of Gambling Behavior.
Brown RI. (1987b). Dropouts and continuers in Gamblers Anonymous: IV. Evaluation and summary. Journal of Gambling Behavior.
Brown SA. (1996). Division 50 and the College of Professional Psychology: Observations from the Chair of the Division 50 Education and Training Committee. The Addictions Newsletter.
Budney, A.J., and Higgins, S.T. A Community Reinforcement Plus Vouchers Approach: Treating Cocaine Addiction. Therapy Manuals for Drug Addiction: Manual 2. Rockville, MD: National Institute on Drug Abuse, 1998.
Budney AJ, Higgins ST, Delaney DD, Kent L, Bickel WK. (1991). Contingent reinforcement of abstinence with individuals abusing cocaine and marijuana. Journal of Applied Behavior Analysis.
Buhrich N, Weller A, Kevans P. (2000). Misuse of anticholinergic drugs by people with serious mental illness. Psychiatric Services.
Bulik CM, Sullivan PF, Carter FA, Joyce PR. (1997). Lifetime comorbidity of alcohol dependence in women with bulimia nervosa. Addictive Behaviors.
Bulik CM, Sullivan PF, Epstein LH, McKee M, Dahl R. (1992). Drug use in women with anorexia and bulimia nervosa. International Journal of Eating Disorders.
Bulik CM, Sullivan PF, Joyce PR, Carter FA. (1995). Temperament, character, and personality disorder in bulimia nervosa. Journal of Nervous and Mental Disease.
Bureau of Justice Statistics. Criminal Victimization in the United States, 2000: Statistical Tables. Washington, DC: Bureau of Justice Statistics, 2002. www.ojp.usdoj.gov/bjs/pub/pdf/cvus00.pdf[Accessed September 7, 2002].
Burns, D.D. The Feeling Good Handbook. Rev. ed. New York: Plume, 1999.
Burt, M. and Aron, L. America's Homeless II: Populations and Services. Washington, DC: Urban Institute, 2000. www.urban.org/housing/homeless/numbers/index.htm[Accessed September 3, 2002].
Bushnell JA, Wells JE, Hornblow AR, Oakley-Browne MA, Joyce P. (1990). Prevalence of three bulimia syndromes in the general population. Psychological Medicine.
Butcher, J.N., Graham, J.R., Ben-Porath, Y.S., Tellegen, A., Dahlstrom, W.G., and Kaemmer, B. Minnesota Multiphasic Personality Inventory-2 (MMPI-2): Manual for Administration, Scoring and Interpretation (Revised Edition). Minneapolis, MN: University of Minnesota Press, 2001.
Butzin CA, Martin SS, Inciardi JA. (2002). Evaluating component effects of a prison-based treatment continuum. Journal of Substance Abuse Treatment.
Callahan, R.J., and Callahan, J. Thought Field Therapy: Aiding the bereavement process. In: Figley, C.R., and Bride, B.E., eds. Death and Trauma: The Traumatology of Grieving. Philadelphia: Taylor and Francis, 1997. pp. 249–267.
Calloway MO, Morrissey JP. (1998). Overcoming service barriers for homeless persons with serious psychiatric disorders. Psychiatric Services.
Calsyn RJ, Morse GA, Klinkenberg WD, Trusty ML, Allen G. (1998). The impact of Assertive Community Treatment on the social relationships of people who are homeless and mentally ill. Community Mental Health Journal.
Carey KB, Purnine DM, Maisto SA, Carey MP. (2001). Enhancing readiness-to-change substance abuse in persons with schizophrenia: A four-session motivation-based intervention. Behavior Modification.
Carlson MJ, Baker LH. (1998). Difficult, dangerous, and drug seeking: The 3D way to better patient care. American Journal of Public Health.
Carroll JF. (1990). Treating drug addicts with mental health problems in a therapeutic community. Journal of Chemical Dependency Treatment.
Carroll JFX, McGinley JJ. (1998). Managing MICA clients in a modified therapeutic community with enhanced staffing. Journal of Substance Abuse Treatment.
Carroll JFX, McGinley JJ. (2001). A screening form for identifying mental health problems in alcohol/other drug dependent persons. Alcoholism Treatment Quarterly.
Carroll KM. (1996). Relapse prevention as a psychosocial treatment: A review of controlled clinical trials. Experimental and Clinical Psychopharmacology.
Carroll, K.M. A Cognitive-Behavioral Approach: Treating Cocaine Addiction. Therapy Manuals for Drug Addiction: Manual 1. Rockville, MD: National Institute on Drug Abuse, 1998.
Casper RC, Eckert ED, Halmi KA, Goldberg SC, Davis JM. (1980). Bulimia: Its incidence and clinical importance in patients with anorexia nervosa. Archives of General Psychiatry.
Castellani B, Rugle L. (1995). A comparison of pathological gamblers to alcoholics and cocaine misusers on impulsivity, sensation seeking, and craving. International Journal of Addictions.
Castro, F.G., Proescholdbell, R.J., Abeita, L., and Rodriguez, D. Ethnic and cultural minority groups. In: McCrady, B.S., and Epstein, E.E., eds. Addiction: A Comprehensive Guidebook. Oxford University Press, 1999. pp. 499–526.
Center for Mental Health Services. Co-Occurring Psychiatric and Substance Disorders in Managed Care Systems: Standards of Care, Practice Guidelines, Workforce Competencies, and Training Curricula. 1998. www.med.upenn.edu/cmhpsr/pdf/cooccurringfinal.pdf[Accessed February 8, 2001].
Center for Mental Health Services. Cultural Competence Standards in Managed Care Mental Health Services: Four Underserved/Underrepresented Racial/Ethnic Groups. DHHS Publication No (SMA) 00-3457. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001. www.mental health.org/publications/allpubs/SMA00-3457/default.asp[Accessed June 4, 2002].
Center for Mental Health Services. Co-Occurring Disorders: Integrated Dual Disorders Treatment Implementation Resource Kit. Produced under contract no. 280-00-8049 from the Substance Abuse and Mental Health Services Administration's Center for Mental Health Services and a grant from The Robert Wood Johnson Foundation (RWJF). Draft for pilot study. n.p.: n.p., n.d, in development.
Center for Mental Health Services, and Center for Substance Abuse Treatment. Insights and Inroads: Project Highlights of the CMHS and CSAT Collaborative Demonstration Program for Homeless Individuals. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000.
Center for Substance Abuse Treatment. Assessment and Treatment of Patients with Coexisting Mental Illness and Alcohol and Other Drug Abuse. Treatment Improvement Protocol (TIP) Series, Number 9. DHHS Pub. No. (SMA) 95-3061. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994a.
Center for Substance Abuse Treatment. Intensive Outpatient Treatment for Alcohol and Other Drug Abuse. Treatment Improvement Protocol (TIP) Series 8. DHHS Publication No. (SMA) 99-3306. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994b.
Center for Substance Abuse Treatment. Simple Screening Instruments for Outreach for Alcohol and Other Drug Abuse and Infectious Diseases. Treatment Improvement Protocol (TIP) Series 11. DHHS Publication No. (SMA) 94-2094. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994c.
Center for Substance Abuse Treatment. Alcohol and Other Drug Screening of Hospitalized Trauma Patients. Treatment Improvement Protocol (TIP) Series, Number 16. DHHS Pub. No. (SMA) 95-3041. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995a.
Center for Substance Abuse Treatment. Combining Alcohol and Other Drug Abuse Treatment With Diversion for Juveniles in the Justice System. Treatment Improvement Protocol (TIP) Series 21. DHHS Publication No. (SMA) 95-3051. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995b.
Center for Substance Abuse Treatment. Detoxification from Alcohol and Other Drugs. Treatment Improvement Protocol (TIP) Series 19. DHHS Publication No. (SMA) 95-3046. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995c.
Center for Substance Abuse Treatment. Planning for Alcohol and Other Drug Abuse Treatment for Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series 17. DHHS Publication No. (SMA) 00-3461. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995d.
Center for Substance Abuse Treatment. Treating Alcohol and Other Drug Abusers in Rural and Frontier Areas. Technical Assistance Publication (TAP) Series 17. DHHS Publication No. (SMA) 95-3054. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995e.
Center for Substance Abuse Treatment. A Guide to Substance Abuse Services for Primary Care Clinicians. Treatment Improvement Protocol (TIP) Series, Number 24. DHHS Pub. No. (SMA) 97-3139. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1997a.
Center for Substance Abuse Treatment. Demystifying Evaluation: A Manual for Evaluating Your Substance Abuse Treatment Program. Vol. 1. DHHS Publication No. (SMA) 99-3341. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1997b.
Center for Substance Abuse Treatment. Substance Abuse Treatment and Domestic Violence. Treatment Improvement Protocol (TIP) Series, Number 25. DHHS Publication No. (SMA) 97-3163. Rockville, MS: Substance Abuse and Mental Health Services Administration, 1997c.
Center for Substance Abuse Treatment. Supplementary Administration Manual for the Expanded Female Version of the Addiction Severity Index (ASI) Instrument. DHHS Publication No. (SMA) 96-8056. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1997d.
Center for Substance Abuse Treatment. Addiction Counseling Competencies: The Knowledge, Skills, and Attitudes of Professional Practice. Technical Assistance Publication Series 21. DHHS Publication No. (SMA) 98-3171. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998a.
Center for Substance Abuse Treatment. Comprehensive Case Management for Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series 27. DHHS Publication No. (SMA) 98-3222. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998b.
Center for Substance Abuse Treatment. Continuity of Offender Treatment for Substance Use Disorders From Institution to Community. Treatment Improvement Protocol (TIP) Series 30. DHHS Publication No. (SMA) 98-3245. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998c.
Center for Substance Abuse Treatment. Substance Abuse Among Older Adults. Treatment Improvement Protocol (TIP) Series, Number 26. DHHS Pub. No. (SMA) 98-3179. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998d.
Center for Substance Abuse Treatment. Substance Use Disorder Treatment for People With Physical and Cognitive Disabilities. Treatment Improvement Protocol (TIP) Series 29. DHHS Publication No. (SMA) 98-3249. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998e.
Center for Substance Abuse Treatment. Brief Interventions and Brief Therapies for Substance Abuse. Treatment Improvement Protocol (TIP) Series, Number 34. DHHS Publication No. (SMA) 99-3353. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999a.
Center for Substance Abuse Treatment. Enhancing Motivation for Change in Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series, Number 35. DHHS Publication No. (SMA) 99-3354. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999b.
Center for Substance Abuse Treatment. Changing the Conversation: Improving Substance Abuse Treatment. The National Treatment Improvement Plan. Panel Reports, Public Hearings, and Participant Acknowledgements. DHHS Publication No. (SMA) 00-3479. Rockville, MD: Center for Substance Abuse Treatment, 2000a.
Center for Substance Abuse Treatment. Drug, Alcohol, Medical, and Mental Health Services Desired and Received in NTIES. NEDS Fact Sheet 43, July 2000b.
Center for Substance Abuse Treatment. Integrating Substance Abuse Treatment and Vocational Services. Treatment Improvement Protocol (TIP) Series 38. DHHS Publication No. (SMA) 00-3470. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000c.
Center for Substance Abuse Treatment. Substance Abuse Treatment for Persons With Child Abuse and Neglect Issues. Treatment Improvement Protocol (TIP) Series Number 36. DHHS Publication No. (SMA) 00-3357. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000d.
Center for Substance Abuse Treatment. Substance Abuse Treatment for Persons With HIV/AIDS. Treatment Improvement Protocol (TIP) Series 37. DHHS Publication No. (SMA) 00-3459. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000e.
Center for Substance Abuse Treatment. Telling Their Stories: Reflections of the 11 Original Grantees That Piloted Residential Treatment for Women and Children for CSAT. DHHS Publication No. (SMA) 01-3529. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001.
Center for Substance Abuse Treatment. Practice Research Collaboratives: Forging Partnerships. Rockville, MD: Substance Abuse and Mental Health Services Administration, n.d. www.samhsa.gov/centers/csat/content/prc/index.html[Accessed January 28, 2002].
Center for Substance Abuse Treatment. Substance Abuse Treatment: Group Therapy. Treatment Improvement Protocol (TIP) Series 41. DHHS Publication No. (SMA) 05-3991. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2005.
Center for Substance Abuse Treatment. Improving Cultural Competence in Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development a.
Center for Substance Abuse Treatment. Substance Abuse Treatment: Addressing the Specific Needs of Women. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development b.
Center for Substance Abuse Treatment. Substance Abuse Treatment and Trauma. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development d.
Center for Substance Abuse Treatment. Substance Abuse Treatment for Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development e.
Chabrol H, Teissedre F, Saint-Jean M, Teisseyre N, Roge B, Mullet E. (2002). Prevention and treatment of post-partum depression: A controlled randomized study on women at risk. Psychological Medicine.
Challis, J. The Development of a Therapeutic Community for the Dually-Diagnosed—Odyssey House, Auckland. Paper presented at the Australasian Therapeutic Communities Association Conference, Sydney, Australia, 1996.
Chamberlin J, Rogers JA. (1990). Planning a community-based mental health system: Perspective of service recipients. American Psychologist.
Chappel, J.N. Spiritual components of the recovery process. In: Graham, A.W. and Wilford, B.B., eds. Principles of Addiction Medicine. 2d ed. Chevy Chase, MD: American Society of Addiction Medicine, 1998, pp. 725–728.
Charney DA, Paraherakis AM, Gill KJ. (2001). Integrated treatment of comorbid depression and substance use disorders. Journal of Clinical Psychiatry.
Chen CK, Lin SK, Sham PC, Ball D, Loh EW, Hsiao CC, Chiang YL, Ree SC, Lee CH, Murray RM. (2003). Pre-morbid characteristics and co-morbidity of methamphetamine users with and without psychosis. Psychological Medicine.
Chilcoat HD, Breslau N. (1998a). Investigations of causal pathways between PTSD and drug use disorders. Addictive Behaviors.
Chilcoat HD, Breslau N. (1998b). Posttraumatic stress disorder and drug disorders: Testing causal pathways. Archives of General Psychiatry.
Christensen, T. “Association of Problem Gambling Service Administrators membership resource guide.” Unpublished manuscript.
Clark, C., and Rich, A. Boley Centers for Behavioral Health Care, Inc.: Housing related support services. In: Refocusing Upstream: Interim Status Report of the Center for Mental Health Services and Center for Substance Abuse Treatment Collaborative Program to Prevent Homelessness. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999. pp. 61–78.
Clark, D.C., and Fawcett, J. Review of empirical risk factors for evaluation of the suicidal patient. In: Bongar, B.M., ed. Suicide: Guidelines for Assessment, Management, and Treatment. New York: Oxford University Press, 1992. pp. 16–48.
Clear, T., and Braga, A.A. Community Corrections. In: Wilson, J.Q., and Petersilia, J., eds. Crime. San Francisco: Institute for Contemporary Studies, 1995.
Clure C, Brady KT, Saladin ME, Johnson D, Waid R, Rittenbury M. (1999). Attention-deficit/hyperactivity disorder and substance use: Symptom pattern and drug choice. American Journal of Drug and Alcohol Abuse.
Cnaan RA, Blankertz L, Messinger KW, Gardner JR. (1990). Experts' assessment of psychosocial rehabilitation principles. Psychosocial Rehabilitation Journal.
Cocco N, Sharpe L, Blaszczynski A. (1995). Differences in the preferred level of arousal in two sub-groups of problem gamblers: A preliminary report. Journal of Gambling Studies.
Coffey, R., Graver, L., Schroeder, D., Busch, J., Dilonardo, J., Chalk, M., and Buck, J. Mental Health and Substance Abuse Treatment: Results from a Study Integrating Data from State Mental Health, Substance Abuse, and Medicaid Agencies. DHHS Publication No. (SMA) 01-3528. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001.
Cohen C, Onserud H, Monaco C. (1993). Outcomes for the mentally ill in a program for older homeless persons. Hospital and Community Psychiatry.
Cohen LS. (1989). Psychotropic drug use in pregnancy. Hospital & Community Psychiatry.
Cohen LS, Viguera AC, Bouffard SM, Nonacs RM, Morabito C, Collins MH, Ablon JS. (2001). Venlafaxine in the treatment of postpartum depression. Journal of Clinical Psychology.
Collings S, King M. (1994). Ten-year follow-up of 50 patients with bulimia nervosa. British Journal of Psychiatry.
Collins, A.C. and Marks, M.J. Animal models of alcohol-nicotine interactions. In: Fertig, J.B., and Allen, J.P., eds. Alcohol and Tobacco: From Basic Science to Clinical Practice. NIAAA Research Monograph No. 30. Bethesda, MD: National Institutes of Health, National Institute on Alcohol Abuse and Alcoholism, pp. 129–144, 1995.
Comings DE, Rosenthal RJ, Lesieur HR, Rugle LJ, Muhleman D, Chiu C, Dietz G, Gade R. (1996). Study of the dopamine D sub 2 receptor gene in pathological gambling. Pharmacogenetics.
Committee on Opportunities in Drug Abuse Research, Division of Neuroscience and Behavioral Health, Institute of Medicine. Pathways of Addiction: Opportunities in Drug Abuse Research. Washington, DC: National Academy Press, 1996.
Concurrent, V.S. Delayed Treatment for Nicotine Dependence for Patients in Intensive Treatment for Alcohol Dependence. Paper presented at the 9th Annual Meeting of the Society for Research on Nicotine and Tobacco, New Orleans, February 2003.
Condelli WS, Hubbard RL. (1994). Relationship between time spent in treatment and client outcomes from therapeutic communities. Journal of Substance Abuse Treatment.
Connors GJ, Carroll KM, DiClemente CC, Longabaugh R, Donovan DM. (1997). The therapeutic alliance and its relationship to alcoholism treatment participation and outcome. Journal of Consulting and Clinical Psychology.
Conrad, K.J., Matters, M.D., Hanrahan, P., and Luchins, D.J., eds. Homelessness prevention in treatment of substance abuse and mental illness: Logic models and implementation of eight American projects. Alcoholism Treatment Quarterly 17(1–2), 1999.
Copeland, M.E., and Harris, M. Healing the Trauma of Abuse: A Woman's Workbook. Oakland, CA: New Harbinger, 2000.
Corcos M, Nezelof S, Speranza M, Topa S, Girardon N, Guilbaud O, Taieb O, Bizouard P, Halfon O, Venisse JL, Perez-Diaz F, Flament M, Jeammet P. (2001). Psychoactive substance consumption in eating disorders. Eating Behaviors.
Cottler LB, Compton WM, Mager D, Spitznagel EL, Janca A. (1992). Posttraumatic stress disorder among substance users from the general population. American Journal of Psychiatry.
Covington, S.S. Helping Women Recover: A Program for Treating Addiction. San Francisco: Jossey-Bass, 1999.
Covington, S.S. Beyond Trauma: A Healing Journey for Women: Facilitator's Guide. Center City, MN: Hazelden, 2003.
Cramer M. (2002). Under the influence of unconscious process: Countertransference in the treatment of PTSD and substance abuse in women. American Journal of Psychotherapy.
Crockford DN, el-Guebaly N. (1998). Psychiatric comorbidity in pathological gambling: A critical review. Canadian Journal of Psychiatry.
Crome IB. (1999). Substance misuse and psychiatric comorbidity: Towards improved service provision. Drugs: Education, Prevention & Policy.
Cross T. (1988). Cultural Competence Continuum. Focal Point.
Culhane, D.P., Metraux, S., and Hadley, T. The Impact of Supportive Housing for Homeless People with Severe Mental Illness on the Utilization of the Public Health, Corrections, and Emergency Shelter Systems: The New York-New York Initiative. New York: Corporation for Supportive Housing, 2001. intranet.csh.org/publications/NYNYCostStudy.pdf [Accessed September 3, 2002].
Cunningham-Williams, R.M. “Development of a diagnostic gambling assessment: A comprehensive timeline.” Poster presented at Toward a Meaningful Diagnosis of Gambling Disorders: From Theory to Practice. Las Vegas, NV, 2001.
Dalack GW, Healy DJ, Meador-Woodruff JH. (1998). Nicotine dependence in schizophrenia: Clinical phenomena and laboratory findings. American Journal of Psychiatry.
Daley D. (1987). Relapse prevention with substance abusers: Clinical issues and myths. Social Work.
Daley, D.C., and Lis, J.A. Relapse prevention: Intervention strategies for mental health clients with comorbid addictive disorders. In: Washton, A.M., ed. Psychotherapy and Substance Abuse: A Practitioner's Handbook. New York: Guilford Press, 1995. pp. 243–263.
Daley, D.C., and Marlatt, G.A. Relapse prevention: Cognitive and behavioral interventions. In: Lowinson, J.H., Ruiz, P., Millman, R.B., and Langrod, J.G., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins, 1992. pp. 533–542.
Daley DC, Zuckoff A. (1998). Improving compliance with the initial outpatient session among discharged inpatient dual diagnosis clients. Social Work.
Dansereau DF, Joe GW, Simpson DD. (1995). Attentional difficulties and the effectiveness of a visual representation strategy for counseling drug-addicted clients. International Journal of the Addictions.
Dansky BS, Brady KT, Saladin ME. (1998). Untreated symptoms of PTSD among cocaine-dependent individuals: Changes over time. Journal of Substance Abuse Treatment.
Davidson JRT. (2004). Long-term treatment and prevention of posttraumatic stress disorder. Journal of Clinical Psychiatry.
Davis, G.C., and Goldman, B. Somatic therapies. In: Goldman, H.H., ed. Review of General Psychiatry, Third Edition. Norwalk, Connecticut: Appleton & Lange, 1992. pp. 370–390.
Dean M, Stock B, Patterson RJ, Levy G. (1980). Serum protein binding of drugs during and after pregnancy in humans. Clinical Pharmacology and Therapeutics.
Dees SM, Dansereau DF, Simpson DD. (1994). A visual representation system for drug abuse counselors. Journal of Substance Abuse Treatment.
De Leon, G. The Therapeutic Community: Study of Effectiveness. Social and Psychological Adjustment of 400 Dropouts and 100 Graduates from the Phoenix House Therapeutic Community. Treatment Research Monograph Series. DHHS Publication No. (ADM) 84-1286. Rockville, MD: National Institute on Drug Abuse, 1984.
De Leon G. (1989). Psychopathology and substance abuse: What is being learned from research in therapeutic communities. Journal of Psychoactive Drugs.
De Leon, G. Modified therapeutic communities for dual disorders. In: Solomon, J., Zimberg, S., and Shollar, E., eds. Dual Diagnosis: Evaluation, Treatment, Training, and Program Development. New York: Plenum Medical Book Co., 1993a. pp. 147–170.
De Leon, G. Cocaine abusers in therapeutic community treatment. In: Tims, F.M., and Leukefeld, C.G., eds. Cocaine Treatment: Research and Clinical Perspectives. NIDA Research Monograph 135. NIH Publication No. 93-3639. Rockville, MD: National Institute on Drug Abuse, 1993b. pp. 163–189.
De Leon G. (1995). Therapeutic communities for addictions: A theoretical framework. International Journal of the Addictions.
De Leon G. (1996). Integrative recovery: A stage paradigm. Substance Abuse.
De Leon G. (2000a). Modified therapeutic community for homeless mentally ill chemical abusers: Treatment outcomes. American Journal of Drug and Alcohol Abuse.
De Leon, G. The Therapeutic Community: Theory, Model, and Method. New York: Springer Publishers, 2000b.
De Leon G, Hawke J, Jainchill N, Melnick G. (2000a). Therapeutic communities: Enhancing retention in treatment using “Senior Professor” staff. Journal of Substance Abuse Treatment.
De Leon G, Jainchill N. (1982). Male and female drug abusers: Social and psychological status after treatment in a therapeutic community. American Journal of Drug and Alcohol Abuse.
De Leon, G., Melnick, G., and Hawke, J. The motivation-readiness factor in drug treatment: Implications for research and policy. In: Levy, J.A., Stephens, R.C., and McBride, D.C., eds. Emergent Issues in the Field of Drug Abuse. Stamford, CT: JAI Press, 2000b. pp. 103–129.
De Leon G, Sacks S, Staines G, McKendrick K. (1999). Modified therapeutic community for homeless mentally ill chemical abusers: Emerging subtypes. American Journal of Drug and Alcohol Abuse.
De Leon G, Sacks S, Staines GL, McKendrick K. (2000c). Modified therapeutic community for homeless mentally ill chemical abusers: Treatment outcomes. American Journal of Drug and Alcohol Abuse.
De Leon, G., Sacks, S., and Wexler, H.K. Modified prison therapeutic communities for the dual- and multiple-diagnosed offender. In: Leukefeld, C.G., Tims, F., and Farabee, D., eds. Treatment of Drug Offenders: Policies and Issues. New York: Springer Publishing, 2002. pp. 138–148.
de Leon J, Diaz FJ, Rogers T, Browne D, Dinsmore L. (2002). Initiation of daily smoking and nicotine dependence in schizophrenia and mood disorders. Schizophrenia Research.
Dennis, M.L. Global Appraisal of Individual Needs (GAIN) Manual: Administration, Scoring, and Interpretation. Bloomington, IL: Lighthouse Publications, 1998.
Dennis, M.L. Overview of the Global Appraisal of Individual Needs (GAIN). Bloomington, IL: Chestnut Health Systems, 2000. www.chestnut.org/li/gain/gainoverview.html[Accessed February 5, 2001].
Derogatis, L.R. Symptom Checklist-90-Revised (SCL-90-R). Minneapolis, MN: NCS Assessments, 1975.
Derogatis LR, Lipman RS, Covi L. (1973). SCL-90: An outpatient psychiatric rating scale. Preliminary report. Psychopharmacology Bulletin.
Derogatis, L.R., and Spencer, P.M. Administration & Procedures: BSI Manual-I, Clinical Psychometric Research. Baltimore: Clinical Psychometric Research, 1982.
Dimeff, L.A., Comtois, K.A., and Linehan, M.M. Borderline personality disorder. In: Graham, A.W., Schultz, T.K., and Wilford, B.B., eds. Principles of Addiction Medicine. 2d ed. Chevy Chase, MD: American Society of Addiction Medicine, 1998. pp. 1063–1079.
Ditton, P.M. Mental Health and Treatment of Inmates and Probationers. Washington, DC: Bureau of Justice Statistics, 1999. www.ojp.usdoj.gov/bjs/pub/ascii/mhtip.txt[Accessed June 15, 2001].
Dixon L, Postrado L, Delahanty J, Fischer PJ, Lehman A. (1999). The association of medical comorbidity in schizophrenia with poor physical and mental health. Journal of Nervous and Mental Disease.
Donaldson, M.S., Yordy, K.D., Lohr, K.N., and Vanselow, N.A., eds. Primary Care: America's Health in a New Era. Washington, DC: National Academy Press, 1996.
Doren, D.M. Understanding and Treating the Psychopath. New York: John Wiley and Sons, 1987.
Dowson, J.H., and Grounds, A.T. Personality Disorders: Recognition and Clinical Management. New York: Cambridge University Press, 1995.
Drake RE, Bartels SJ, Teague GB, Noordsy DL, Clark RE. (1993). Treatment of substance abuse in severely mentally ill patients. Journal of Nervous and Mental Disease.
Drake RE, McHugo GJ, Clark RE, Teague GB, Xie H, Miles K, Ackerson TH. (1998a). Assertive Community Treatment for patients with co-occurring severe mental illness and substance use disorder: A clinical trial. American Journal of Orthopsychiatry.
Drake RE, Mercer-McFadden C, Mueser KT, McHugo GJ, Bond GR. (1998b). Review of integrated mental health and substance abuse treatment for patients with dual disorders. Schizophrenia Bulletin.
Drake RE, Mueser KT. (1996a). Alcohol use disorder and severe mental illness. Alcohol Health and Research World.
Drake, R.E., and Mueser, K.T., eds. Dual Diagnosis of Major Mental Illness and Substance Abuse Disorder II: Recent Research and Clinical Implications. New Directions for Mental Health Services. San Francisco, CA: Jossey-Bass, Inc., 1996b. p. 70.
Drake RE, Mueser KT. (2000). Psychosocial approaches to dual diagnosis. Schizophrenia Bulletin.
Drake RE, Mueser KT, Clark RE, Wallach MA. (1996a). The course, treatment, and outcome of substance disorder in persons with severe mental illness. American Journal of Orthopsychiatry.
Drake, R.E., Mueser, K.T., and McHugo, G.J. Clinician rating scales: Alcohol Use Scale (AUS), Drug Use Scale (DUS), and Substance Abuse Treatment Scale (SATS). In: Sederer, L.I., and Dickey, B., eds. Outcomes Assessment in Clinical Practice. Baltimore: Williams & Wilkins, 1996b, pp. 113–­116.
Drake RE, Yovetich NA, Bebout RR, Harris M. (1997). Integrated treatment for dually diagnosed homeless adults. Journal of Nervous and Mental Disease.
Drewnowski A, Hopkins SA, Kessler RC. (1988). The prevalence of bulimia nervosa in the US college student population. American Journal of Public Health.
Drozdick J, Berghella V, Hill M, Kaltenbach K. (2002). Methadone trough levels in pregnancy. American Journal of Obstetrics and Gynecology.
Duffy, S.Q. Substance use and mental disorder discharges from U.S. community hospitals in the early 1990s, revisited. In: Council, C.L., ed. Health Services Utilization by Individuals with Substance Abuse and Mental Disorders. DHHS Publication No. SMA 04-3949, Analytic Series A-25. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2004.
DuPont, R.L. The twelve-step approach. In: Miller, N.S., ed. Treating Coexisting Psychiatric and Addictive Disorders: A Practical Guide. Center City, MN: Hazelden Educational Materials, 1994. pp. 177–178.
DuPont RL. (1997). Panic disorder and addiction: The clinical issues of comorbidity. Bulletin of the Menninger Clinic.
Eddy KT, Keel PK, Dorer DJ, Delinsky SS, Franko DL, Herzog DB. (2002). Longitudinal comparison of anorexia nervosa subtypes. International Journal of Eating Disorders.
Edens JF, Peters RH, Hills HA. (1997). Treating prison inmates with co-occurring disorders: An integrative review of existing programs. Behavioral Sciences and the Law.
Etheridge RM, Hubbard RL, Anderson J, Craddock SG, Flynn PM. (1997). Treatment structure and program services in the Drug Abuse Treatment Outcome Study (DATOS). Psychology of Addictive Behavior.
Evans, K., and Sullivan, J.M. Step Study Counseling with the Dual Disordered Client. Center City, MN: Hazelden Educational Materials, 1990.
Evans, K., and Sullivan, J.M. Treating Addicted Survivors of Trauma. New York: Guilford Press, 1995.
Evans, K., and Sullivan, J.M. Dual Diagnosis: Counseling the Mentally Ill Substance Abuser. 2d ed. New York: Guilford Press, 2001.
Falsetti SA, Resnick HS, Resnick PA, Kilpatrick D. (1993). The Modified PTSD Symptom Scale: A brief self-report measure of posttraumatic stress disorder. The Behavioral Therapist.
Farmer R. (1995). Stress and working with drug misusers. Addiction Research.
Finkelstein, N., Kennedy, C., Thomas, K., and Kearns, M. Gender-Specific Substance Abuse Treatment. Rockville, MD: Center for Substance Abuse Prevention, 1997.
Finnegan, L.P., and Wapner, R.J. Narcotic addiction in pregnancy. In: Niebyl, J.R., ed. Drug Use in Pregnancy. 2d ed. Philadelphia: Lea and Febiger, 1988. pp. 203–222.
Fiore MC. (2000). Treating tobacco use and dependence: An introduction to the US Public Health Service Clinical Practice Guideline. Respiratory Care.
Fiore, M.C., Bailey, W.C., Cohen, S., Dorfman, S.F., Goldstein, M., Gritz, E.R., Heyman, R.B., Jaen, C.R., Kottke, T.E., Lando, H.A., Mecklenburg, R.E., Mullen, P.D., Nett, L.M., Robinson, L., Stitzer, M.L., Tommasello, A.C., Villejo, L., Wewers, M.E., Baker, T., Fox, D.M., and Hasselblad, V. Treating Tobacco Use and Dependence: A Clinical Practice Guideline. Rockville, MD: Public Health Service, 2000a.
Fiore, M.C., Bailey, W.C., Cohen, S.J., Dorfman, S.F., Goldstein, M.G., Gritz, E.R., Heyman, R.B., Jaen, C.R., Kottke, T.E., Lando, H.A., Mecklenburg, R.E., Mullen, P.D., Nett, L.M., Robinson, L., Stitzer, M.L., Tommasello, A.C., Villejo, L., and Wewers, M.E. Treating Tobacco Use and Dependence: Quick Reference Guide for Clinicians. Rockville, MD: Public Health Service, 2000b. www.surgeongeneral.gov/tobacco/tobaqrg.htm[Accessed June 4, 2002].
Fiorentine R, Nakashima J, Anglin MD. (1999). Client engagement in drug treatment. Journal of Substance Abuse Treatment.
Fischer PJ, Breakey WR. (1987). Profile of the Baltimore homeless with alcohol problems. Alcohol Health and Research World.
Fischer PJ, Breakey WR. (1991). Epidemiology of alcohol, drug and mental disorders among homeless persons. American Psychologist.
Fisher MS. (1995). Group therapy protocols for persons with personality disorders who abuse substances: Effective treatment alternatives. Social Work With Groups.
Flavin, D.K., Franklin, J.E., and Frances, R.J. Substance abuse and suicidal behavior. In: Blumenthal, S.J., and Kupfer, D.J., eds. Suicide Over the Life Cycle: Risk Factors, Assessment, and Treatment of Suicidal Patients. Washington, DC: American Psychiatric Press, 1990. pp. 177–204.
Fletcher BW, Tims FM, Brown BS. (1997). Drug Abuse Treatment Outcome Study (DATOS): Treatment evaluation research in the United States. Psychology of Addictive Behavior.
Flory K, Milich R, Lynam DR, Leukefeld C, Clayton R. (2003). Relation between childhood disruptive behavior disorders and substance use and dependence symptoms in young adulthood: Individuals with symptoms of attention-deficit/hyperactivity disorder and conduct disorder are uniquely at risk. Psychology of Addictive Behaviors.
Fluoxetine Bulimia Nervosa Collaborative Study Group. (1992). Fluoxetine in the treatment of bulimia nervosa: A multicenter, placebo-controlled, double-blind trial. Archives of General Psychiatry.
Flynn PM, Craddock SG, Hubbard RL, Anderson J, Etheridge RM. (1997). Methodological overview and research design for the drug abuse treatment outcome study (DATOS). Psychology of Addictive Behaviors.
Flynn PM, Craddock SG, Luckey JW, Hubbard RL, Dunteman GH. (1996). Comorbidity of antisocial personality and mood disorders among psychoactive substance-dependent treatment clients. Journal of Personality Disorders.
Foa, E.B., Keane, T.M., and Friedman, M.J. (eds). Effective Treatment for PTSD. New York: The Guilford Press, 2000.
Foa EB, Riggs DS, Dancu CV, Rothbaum BO. (1993). Reliability and validity of a brief instrument for assessing post-traumatic stress disorder. Journal of Traumatic Stress.
Foa, E.B., and Rothbaum, B.O. Treating the Trauma of Rape: Cognitive-Behavioral Therapy for PTSD. New York: Guilford Press, 1998.
Follete, V.M., Ruzek, J.I., and Abueg, F.R. (eds). Cognitive-Behavioral Therapies for Trauma. New York: The Guilford Press, 1998.
Forbes D, Creamer M, Hawthorne G, Allen N, McHugh T. (2003). Comorbidity as a predictor of symptom change after treatment in combat-related posttraumatic stress disorder. Journal of Nervous and Mental Disease.
Ford, J., Kasimer, N., MacDonald, M., and Savill, G. Trauma Adaptive Recovery Group Education and Therapy (TARGET): Participant Guidebook and Leader Manual. Farmington, CT: University of Connecticut Health Center, 2000.
Forrest, G.G. Countertransference in Chemical Dependency Counseling. Binghamton, NY: Haworth Press, 2002.
Fowler IL, Carr VJ, Carter NT, Lewin TJ. (1998). Patterns of current and lifetime substance use in schizophrenia. Schizophrenia Bulletin.
Foulds J, Burke M, Steinberg M, Ziedonis DM. (2004). Advances in pharmacotherpay for tobacco dependence. Expert Opinion on Emerging Drugs.
Frank AF, Gunderson JG. (1990). The role of the therapeutic alliance in the treatment of schizophrenia: Relationship to course and outcome. Archives of General Psychiatry.
French MT, McCollister KE, Sacks S, McKendrick K, De Leon G. (2002). Benefit-cost analysis of a modified therapeutic community for mentally ill chemical abusers. Evaluation and Program Planning.
French MT, Sacks S, De Leon G, Staines G, McKendrick K. (1999). Modified therapeutic community for mentally ill chemical abusers: Outcomes and costs. Evaluation & the Health Professions.
French MT, Salome HJ, Krupski A, McKay JR, Donovan DM, McLellan AT, Durell J. (2000). Benefit-cost analysis of residential and outpatient addiction treatment in the State of Washington. Evaluation Review.
Frosch DL, Shoptaw S, Nahom D, Jarvik ME. (2000). Associations between tobacco smoking and illicit drug use among methadone-maintained opiate-dependent individuals. Experimental and Clinical Psychopharmacology.
Frosch DL, Stein JA, Shoptaw S. (2002). Using latent-variable models to analyze smoking cessation clinical trial data: An example among the methadone maintained. Experimental and Clinical Psychopharmacology.
Fullilove MT, Fullilove RE, Smith M, Winkler K. (1993). Violence, trauma, and post-traumatic stress disorder among women drug users. Journal of Traumatic Stress.
Galanter M., ed. Recent Developments in Alcoholism, Vol. VII: Treatment Issues. New York: Plenum Press, 1989.
Galanter M, Castaneda R, Ferman J. (1988). Substance abuse among general psychiatric patients: Place of presentation, diagnosis, and treatment. American Journal of Drug and Alcohol Abuse.
Galanter M, Dermatis H, Egelko S, De Leon G. (1998). Homelessness and mental illness in a professional- and peer-led cocaine treatment clinic. Psychiatric Services.
Galanter, M., Franco, H., Kim, A., Metzger, E.J., and De Leon, G. Inpatient treatment for the dually diagnosed: A peer-led model for acute and intermediate care. In: Solomon, J., Zimberg, S., and Shollar, E., eds. Dual Diagnosis: Evaluation, Treatment, Training, and Program Development. New York: Plenum Medical Book Co., 1993. pp. 171–192.
Ganrot PO. (1972). Variation of the concentrations of some plasma proteins in normal adults, in pregnant women and in newborns. Scandinavian Journal of Clinical and Laboratory Investigation Supplementum.
Garbis, H., and McElhatton, P.R. Psychotropic, sedative-hypnotic and Parkinson drugs. In: Drugs During Pregnancy and Lactation; Handbook of Prescription Drugs and Comparative Risk Assessment: With Updated Information on Recreational Drugs. New York: Elsevier, 2001. pp. 182–191.
Garfinkel PE, Lin E, Goering P, Spegg C, Goldbloom DS, Kennedy S, Kaplan AS, Woodside DB. (1995). Bulimia nervosa in a Canadian community sample: Prevalence and comparison of subgroups. American Journal of Psychiatry.
Garfinkel PE, Moldofsky H, Garner DM. (1980). The heterogeneity of anorexia nervosa: Bulimia as a distinct subgroup. Archives of General Psychiatry.
Gentilello LM, Rivara FP, Donovan DM, Jurkovich GJ, Daranciang E, Dunn CW, Villaveces A, Copass M, Ries RR. (1999). Alcohol interventions in a trauma center as a means of reducing the risk of injury recurrence. Annals of Surgery.
George TP, Ziedonis DM, Feingold A, Pepper WT, Satterburg CA, Winkel J, Rounsaville BJ, Kosten TR. (2000). Nicotine transdermal patch and atypical antipsychotic medications for smoking cessation in schizophrenia. American Journal of Psychiatry.
Gerber S, Basham A. (1999). Responsive therapy and motivational interviewing: Postmodernist paradigms. Journal of Counseling and Development.
Gerstein, D.R., and Harwood, H.J., eds. Treating Drug Problems: Vol. 1. A Study of the Evolution, Effectiveness, and Financing of Public and Private Drug Treatment Systems. Washington, DC: National Academy Press, 1990.
Gerstein, D., Murphy, S., Toce, M., Hoffmann, J., Palmer, A., Johnson, R., Larison, C., Churchro, L., Buie, T., Engleman, L., Hill, M., Volberg, R., Harwood, H., Tucker, A., Christensen, E., Cummings, W., and Sinclair, S. Gambling Impact and Behavior Study: A Report to the National Gambling Impact Study Commission. Chicago: National Opinion Research Center, 1999. www.norc.uchicago.edu/new/pdf/gamble.pdf[Accessed February 4, 2002].
Gil-Rivas V, Fiorentine R, Anglin MD. (1996). Sexual abuse, physical abuse, and posttraumatic stress disorder among women participating in outpatient drug abuse treatment. Journal of Psychoactive Drugs.
Gilbert, D.G. Smoking: Individual Difference, Psychopathology, and Emotion. The Series in Health Psychology and Behavioral Medicine. Washington, DC: Taylor and Francis, 1995.
Godley SH, Godley MD, Pratt A, Wallace JL. (1994). Case management services for adolescent substance abusers: A program description. Journal of Substance Abuse Treatment.
Goff DC, Henderson DC, Amico E. (1992). Cigarette smoking in schizophrenia: Relationship to psychopathology and medication side effects. American Journal of Psychiatry.
Goldbloom DS, Naranjo CA, Bremner KE, Hicks LK. (1992). Eating disorders and alcohol abuse in women. British Journal of Addiction.
Goldenberg IM, Mueller T, Fierman EJ, Gordon A, Pratt L, Cox K, Park T, Lavori P, Goisman RM, Keller MB. (1995). Specificity of substance use in anxiety-disordered subjects. Comprehensive Psychiatry.
Goldfinger SM. (2000). Integrated treatment for dual diagnosis. The Advocate.
Goldman HH. (1998). Deinstitutionalization and community care. Harvard Review of Psychiatry.
Goldsmith, R.J., and Ries, R.K. Substance-induced mental disorders. In: Graham, A.W., Schultz, T.K., and Wilford, B.B., eds. Principles of Addiction Medicine. 2d ed. Chevy Chase, MD: American Society of Addiction Medicine, 1998. pp. 969–981.
Goldstein RB, Powers SI, McCusker J. (1999). Erratum to “Antisocial behavioral syndromes among residential drug abuse treatment clients”. Drug & Alcohol Dependence.
Gomberg, E.S.L. Alcohol abuse: Age and gender differences. In: Wilsnack, R.W., and Wilsnack, S.C., eds. Gender and Alcohol: Individual and Social Perspectives. New Brunswick, NJ: Rutgers Centers of Alcohol Studies, 1997. pp. 225–244.
Goodwin, F.K., and Jamison, K.R. Manic-Depressive Illness. New York: Oxford University Press, 1990.
Gorski, T.T. The CENAPS model of relapse prevention therapy (CMRPT). In: Boren, J.J., Onken, L.S., and Carroll, K.M., eds. Approaches to Drug Abuse Counseling. NIH Publication No. 00-4151. Bethesda, MD: National Institute on Drug Abuse, 2000. pp. 23–38.
Gould F, Levine M, McLellan AT. (2000). Treating the substance-abusing patient in the public sector: “Medical necessity” versus “social necessity and social responsibility” in the Philadelphia Target Cities demonstration project. Journal of Substance Abuse Treatment.
Grant, B.F. The influence of comorbid major depression and substance use disorders on alcohol and drug treatment: Results of a national survey. In: Onken, L.S., Blaine, J.D., Genser, S., and Horton, A.M., eds. Treatment of Drug-Dependent Individuals with Comorbid Mental Disorders. NIDA Research Monograph 172. NIH Publication No. 97-4172. Rockville, MD: National Institute on Drug Abuse, 1997. pp. 4–15.
Grella CE. (1997). Services for perinatal women with substance abuse and mental health disorders: The unmet need. Journal of Psychoactive Drugs.
Greene DC, McVinney LD. (1997). Outpatient group psychotherapy with chemically dependent and cluster-B personality disordered male clients. Journal of Chemical Dependency Treatment.
Grice DE, Brady KT, Dustan LR, Malcolm R, Kilpatrick DG. (1995). Sexual and physical assault history and posttraumatic stress disorder in substance-dependent individuals. American Journal on Addictions.
Grieger TA, Fullerton CS, Ursano RJ. (2003). Posttraumatic stress disorder, alcohol use, and perceived safety after the terrorist attack on the Pentagon. Psychiatric Services.
Griffith JD, Hiller ML, Knight K, Simpson DD. (1999). A cost-effectiveness analysis of in-prison therapeutic community treatment and risk classification. The Prison Journal.
Griffiths EJ, Lorenz RP, Baxter S, Talon NS. (1989). Acute neurohumoral response to electroconvulsive therapy during pregnancy: A case report. Journal of Reproductive Medicine.
Griffiths RR. (1980). Common factors in human and infrahuman drug self-administration. Psychopharmacology Bulletin.
Grosch, W.N., and Olsen, D.C. When Helping Starts To Hurt: A New Look at Burnout Among Psychotherapists. New York: W.W. Norton, 1994.
Gruber AJ, Pope HG. (1994). Cannabis psychotic disorder: Does it exist?. American Journal of Addiction.
Gustafson, J.S., Anderson, R., Sheehan, K., McGencey, S., Reda, J., O'Donnell, C., Strohl, J.B., Moghul, A., Clemmey, P., and Spencer, J. State Resources and Services Related to Alcohol and Other Drug Problems: Fiscal Years 1996 and 1997. Washington, DC: National Association of State Alcohol and Drug Abuse Directors, 1999.
Gustafson, J.S., Reda, J., McMullen, H., Sheehan, K., McGencey, S., Rugaber, C., Anderson, R., and DiCarlo, M. State Resources and Services Related to Alcohol and Other Drug Problems for Fiscal Year 1995: An Analysis of State Alcohol and Drug Abuse Profile Data. Washington, DC: National Association of State Alcohol and Drug Abuse Directors, 1997.
Guydish, J., Werdegar, D., Chan, M., Nebelkopf, E., and Acampora, A. Challenges in developing a drug abuse day treatment program. In: Fletcher, B., and Horton, A.M., eds. Drug Abuse Treatment: The Implementation of Innovative Approaches. Westport, CT: Greenwood Press, 1994. pp. 195–207.
Hajek P, West R, Lee A, Foulds J, Owen L, Eiser JR, Main N. (2001). Randomized controlled trial of a midwife-delivered brief smoking cessation intervention in pregnancy. Addiction.
Hall A, Slim E, Hawker F, Salmond C. (1984). Anorexia nervosa: Long-term outcome in 50 female patients. British Journal of Psychiatry.
Hall GW, Carriero NJ, Takushi RY, Montoya ID, Preston KL, Gorelick DA. (2000). Pathological gambling among cocaine-dependent outpatients. American Journal of Psychiatry.
Hall RG, Duhamel M, McClanahan R, Miles G, Nason C, Rosen S, Schiller P, Tao-Yonenaga L, Hall SM. (1995). Level of functioning, severity of illness, and smoking status among chronic psychiatric patients. Journal of Nervous and Mental Disease.
Hall SM. (1999). Psychological interventions: State of the art. Nicotine and Tobacco Research.
Hall SM, Munoz RF, Reus VI, Sees KL, Duncan C, Humfleet GL, Hartz DT. (1996). Mood management and nicotine gum in smoking treatment: A therapeutic contact and placebo-controlled study. Journal of Consulting and Clinical Psychology.
Hall SM, Munoz RF, Reus VI. (1994). Cognitive-behavioral intervention increases abstinence rates for depressive-history smokers. Journal of Consulting and Clinical Psychology.
Hall SM, Reus VI, Munoz RF, Sees KL, Humfleet G, Hartz DT, Frederick S, Triffleman E. (1998). Nortriptyline and cognitive-behavioral therapy in the treatment of cigarette smoking. Archives of General Psychiatry.
Ham LS, Hope DA. (2003). Alcohol and anxiety: Subtle and obvious attributes of abuse in adults with social anxiety disorder and panic disorder. Depression and Anxiety.
Hamilton M. (1959). The assessment of anxiety states by rating. British Journal of Medical Psychology.
Hamilton, T. Dual diagnosis recovery can be a long process. The Bell December 7, 1999.
Hamilton, T. Dual recovery. New York City Voices 5(3), 2000. www.newyorkcityvoices.org/may00s.html[Accessed September 9, 2002].
Hamilton, T. Dual Recovery, Self-Help Support (Part One). Nashville, TN: Dual Diagnosis Recovery Network, 2001. www.dualdiagnosis.org/library/dual_network/hamilton_fall_01.html[Accessed February 5, 2002].
Han, C., and Wisdom, G. Sexually Abused Women in Substance Abuse Treatment: Outcomes. NEDS Fact Sheet 20. Fairfax, VA: National Evaluation Data Services, 1999.
Hare RD. (1998). The Hare PCL-R: Some issues concerning its use and misuse. Legal and Criminological Psychology.
Hargreaves, W.A., Shumway, M., Hu, T.W., and Cuffel, B. Cost-Outcome Methods for Mental Health. San Diego, CA: Academic Press, 1998.
Harris B, Lovett L, Newcombe RG, Read GF, Walker R, Riad-Fahmy D. (1994). Maternity blues and major endocrine changes: Cardiff puerperal mood and hormone study II. British Medical Journal.
Harris M. (1994). Modifications in service delivery and clinical treatment for women diagnosed with severe mental illness who are also the survivors of sexual abuse trauma. Journal of Mental Health Administration.
Harris M. (1996). Treating sexual abuse trauma with dually diagnosed women. Community Mental Health Journal.
Harris, M., and Community Connections Trauma Work Group. Trauma Recovery and Empowerment: A Clinician's Guide for Working with Women in Groups. New York: Simon & Schuster, 1998.
Harris, M., and Fallot, R.D. Designing trauma-informed addictions services. In: Harris, M., and Fallot, R.D., eds. Using Trauma Theory to Design Service Systems. New Directions for Mental Health Services, No. 89. San Francisco: Jossey-Bass, 2001. pp. 57–73.
Hartman EA, Feinauer D. (1994). Human resources for the next decade. Administration and Policy in Mental Health.
Hatsukami D, Mitchell JE, Eckert ED, Pyle R. (1986). Characteristics of patients with bulimia only, bulimia with affective disorder, and bulimia with substance abuse problems. Addictive Behaviors.
Haustein KO, Haffner S, Woodcock BG. (2002). A review of the pharmacological and psychopharmacological aspects of smoking and smoking cessation in psychiatric patients. International Journal of Clinical Pharmacology and Therapeutics.
Health Care Financing Administration. Key Approaches to the Use of Managed Care Systems for Persons with Special Health Care Needs: Guidance for States Considering the Development Medicaid Managed Care Programs for Persons with Special Needs. Baltimore, MD: Health Care Financing Administration, 1998. www.hcfa.gov/medicaid/letters/smd%2Dsnpf.htm[Accessed January 28, 2002].
Hedlung JL, Vieweg BW. (1979). The Hamilton Rating Scale for Depression: A comprehensive review. Journal of Operational Psychiatry.
Hendrickson, E., and Schmal, M. “Dual Diagnosis Treatment: An 18-Year Perspective.” Paper presented at the MISA Conference sponsored by MCP-Hahnemann University, Philadelphia, September 2000.
Hendrickson, E., Schmal, M., Albert, N., and Massaro, J. Dual Disorder Treatment: Perspectives on the State of the Art. New York: The Information Exchange (TIE), 1994. www.toad.net/~arcturus/dd/tline2.htm[Accessed February 5, 2002].
Hendrickson EL, Schmal MS, Cousins J. (1996). Modifying group treatment for seriously mentally ill substance abusers. The Counselor.
Henzel HA. (1984). Diagnosing alcoholism in patients with anorexia nervosa. American Journal of Drug and Alcohol Abuse.
Herman, J.L. Trauma and Recovery. Rev. ed. New York: Basic Books, 1997.
Herzog DB, Keller MB, Sacks NR, Yeh CJ, Lavori PW. (1992). Psychiatric comorbidity in treatment-seeking anorexics and bulimics. Journal of the American Academy of Child and Adolescent Psychiatry.
Herzog W, Deter HC, Fiehn W, Petzold E. (1997). Medical findings and predictors of long-term physical outcome in anorexia nervosa: A prospective, 12-year follow-up study. Psychological Medicine.
Higgins, S.T. Potential contributions of the community reinforcement approach and contingency management to broadening the base of substance abuse treatment. In: Tucker, J.A., Donovan, D.M., and Marlatt, G.A., eds. Changing Addictive Behavior: Bridging Clinical and Public Health Strategies. New York: Guilford Press, 1999. pp. 283–306.
Higgins ST, Petry NM. (1999). Contingency management: Incentives for sobriety. Alcohol Research and Health.
Higgins ST, Stitzer ML, Bigelow GE, Liebson IA. (1986). Contingent methadone delivery: Effects on illicit-opiate use. Drug and Alcohol Dependence.
Hiller ML. (1998). Legal pressure and treatment retention in a national sample of long-term residential programs. Criminal Justice & Behavior.
Hiller ML, Knight K, Broome KM, Simpson DD. (1998). Legal pressure and treatment retention in a national sample of long-term residential programs. Criminal Justice & Behavior.
Hiller ML, Knight K, Simpson DD. (1999). Prison-based substance abuse treatment, residential aftercare and recidivism. Addiction.
Hockey S, Brown LJ, Lunt H. (1993). Prevalence of insulin self-manipulation in young women with insulin dependent diabetes. New Zealand Medical Journal.
Hoek HW. (1991). The incidence and prevalence of anorexia nervosa and bulimia nervosa in primary care. Psychological Medicine.
Hoek HW, van Hoeken D. (2003). Review of the prevalence and incidence of eating disorders. International Journal of Eating Disorders.
Hoffmann, N.G., Mee-Lee, D., and Shulman, G.D. LOCI-2R: Level of Care Index-2R. Smithfield, RI: Evince Clinical Assessments, 2001.
Holderness CC, Brooks-Gunn J, Warren MP. (1994). Co-morbidity of eating disorders and substance abuse: Review of the literature. International Journal of Eating Disorders.
Hollander E, DeCaria CM, Finkell JN, Begaz T, Wong CM, Cartwright C. (2000). A randomized double-blind fluvoxamine/placebo crossover trial in pathologic gambling. Biological Psychiatry.
Hubbard RL, Craddock SG, Flynn PM, Anderson J, Etheridge RM. (1997). Overview of 1-year follow-up outcomes in the Drug Abuse Treatment Outcome Study (DATOS). Psychology of Addictive Behaviors.
Hubbard, R.L., Marsden, M.E., Rachal, J.V., Harwood, H.J., Cavanaugh, E.R., and Ginzburg, H.M. Drug Abuse Treatment: A National Study of Effectiveness. Chapel Hill, NC: University of North Carolina Press, 1989.
Hubbard, R.L., Rachal, J.V., Craddock, S.G., and Cavanaugh, E.R. Treatment Outcome Prospective Study (TOPS): Client characteristics and behaviors before, during, and after treatment. In: Tims, F.M., and Ludford, P.J., eds. Drug Abuse Treatment Evaluation: Strategies, Progress, and Prospects. NIDA Research Monograph 51. Washington, DC: Superintendent of Documents, US Government Printing Office, 1984. pp. 42–68.
Hudson JI, Pope HG, Jonas JM, Yurgelun-Todd D. (1983a). Family history study of anorexia nervosa and bulimia. British Journal of Psychiatry.
Hudson JI, Pope HG, Jonas JM, Yurgelun-Todd D. (1983b). Phenomenologic relationship of eating disorders to major affective disorder. Psychiatry Research.
Hudson JI, Weiss RD, Pope HG, McElroy SK, Mirin SM. (1992). Eating disorders in hospitalized substance abusers. American Journal of Drug and Alcohol Abuse.
Hughes, J.R. Clinical implications of the association between smoking and alcoholism. In: Fertig, J.B., and Allen, J.P., eds. Alcohol and Tobacco: From Basic Science to Clinical Practice. NIAAA Research Monograph No. 30. NIH Publication No. 95–3931. Bethesda, MD: National Institute on Alcohol Abuse and Alcoholism, pp. 171–185, 1995.
Hughes JR. (1996). Treating smokers with current or past alcohol dependence. American Journal of Health Behavior.
Hughes JR, Rose GL, Callas PW. (2000). Nicotine is more reinforcing in smokers with a past history of alcoholism than in smokers without this history. Alcoholism: Clinical and Experimental Research.
Hurlburt MS, Hough RL, Wood PA. (1996). Effects of substance abuse on housing stability of homeless mentally ill persons in supported housing. Psychiatric Services.
Hurt RD, Eberman KM, Croghan IT, Offord KP, Davis LJ, Morse RM, Palmen M, Bruce BK. (1994). Nicotine dependence treatments during inpatient treatment for other addictions: A prospective intervention trial. Alcoholism: Clinical and Experimental Research.
Hurt RD, Offord KP, Croghan IT, Gomez-Dahl L, Kottke TE, Morse RM, Melton LJ. (1996). Mortality following inpatient addictions treatment: Role of tobacco use in a community-based cohort. Journal of the American Medical Association.
Hser Y, Grella C, Hubbard RL, Hsieh S, Fletcher BW, Brown BS, Anglin MD. (2001). An evaluation of drug treatment for adolescents in 4 US cities. Archives of General Psychiatry.
Inciardi, J.A., Martin, S.S., and Surratt, H.L. Therapeutic communities in prisons and work release: Effective modalities for drug-involved offenders. In: Rawlings, B., and Yates, R., eds. Therapeutic Communities for the Treatment of Drug Users. London: Jessica Kingsley Publishers, 2001.
Inskip HM, Harris EC, Barraclough B. (1998). Lifetime risk of suicide for affective disorder, alcoholism and schizophrenia. British Journal of Psychiatry.
Institute of Medicine. Homelessness, Health, and Human Needs. Washington, DC: National Academy Press, 1988.
Institute of Medicine. Pathways of Addiction: Opportunities in Drug Abuse Research. Washington, DC: National Academy Press, 1996.
Integrating Systems of Care: What We Know From ACCESS. Delmar, NY: National Resource Center on Homelessness and Mental Illness, 1999. www.nrchmi.com/access/5_99_b.asp[Accessed March 15, 2002].
Irvin JE, Bowers CA, Dunn ME, Wang MC. (1999). Efficacy of relapse prevention: A meta-analytic review. Journal of Consulting and Clinical Psychology.
Jacobsen LK, Southwick SM, Kosten TR. (2001). Substance use disorders in patients with posttraumatic stress disorder: A review of the literature. American Journal of Psychiatry.
Jerrell JM, Hu TW, Ridgely MS. (1994). Cost-effectiveness of substance disorder interventions for people with severe mental illness. Journal of Mental Health Administration.
Jerrell JM, Ridgely MS. (1995). Gender differences in the assessment of specialized treatments for substance abuse among people with severe mental illness. Journal of Psychoactive Drugs.
Jerrell JM, Wilson JL. (1997). Ethnic differences in the treatment of dual mental and substance disorders: A preliminary analysis. Journal of Substance Abuse Treatment.
Joe GW, Brown BS, Simpson D. (1995). Psychological problems and client engagement in methadone treatment. Journal of Nervous and Mental Disease.
Joe GW, Knezek L, Watson D, Simpson DD. (1991). Depression and decision-making among intravenous drug users. Psychological Reports.
Johnson CL, Stuckey MK, Lewis LD, Schwartz DM. (1982). Bulimia: A descriptive survey of 316 cases. International Journal of Eating Disorders.
Johnson DM, Shea MT, Yen S, Battle CL, Zlotnick C, Sanislow CA, Grilo CM, Skodol AE, Bender DS, McGlashan TH, Gunderson JG, Zanarini MC. (2003). Gender differences in borderline personality disorder: Findings from the Collaborative Longitudinal Personality Disorders Study. Comprehensive Psychiatry.
Johnson EE, Hamer R, Nora RM, Tan B, Eisenstein N, Engelhart C. (1997). The Lie/Bet Questionnaire for screening pathological gamblers. Psychological Reports.
Johnson, G., and Hunter, R.M. Evaluation of the specialized drug offender program. In: Ross, R.R., and Ross, R.D., eds. Thinking Straight: The Reasoning and Rehabilitation Program for Delinquency Prevention and Offender Rehabilitation. Ottawa, Ontario: Air Training and Publications, 1995. pp. 215–234.
Johnson-Sabine E, Wood K, Patton G, Mann A, Wakeling A. (1988). Abnormal eating attitudes in London schoolgirls: A prospective epidemiological study. Factors associated with abnormal response on screening questionnaires. Psychological Medicine.
Jonas JM, Gold MS. (1988). Naltrexone treatment of bulimia: Clinical and theoretical findings linking eating disorders and substance abuse. Advances in Alcohol and Substance Abuse.
Jonas JM, Gold MS, Sweeney D, Pottash AL. (1987). Eating disorders and cocaine abuse: A survey of 259 cocaine abusers. Journal of Clinical Psychiatry.
Jones HE, Johnson RE. (2001). Pregnancy and substance abuse. Current Opinion in Psychiatry.
Jones, H.E., Velez, M.L., McCaul, M.E., and Svikis, D.S. Special treatment issues for women. In: Strain, E.C., and Stitzer, M., eds. Methadone Treatment for Opioid Dependence. Baltimore: Johns Hopkins University Press, 1999. pp. 251–280.
Joseph AM, Nichol KL, Willenbring ML, Korn JE, Lysaght LS. (1990). Beneficial effects of treatment of nicotine dependence during an inpatient substance abuse treatment program. Journal of the American Medical Association.
Joseph AM, Willenbring ML, Nelson D, Nugent SM. (2002). Timing of alcohol and smoking cessation study. Alcoholism: Clinical and Experimental Research.
Karageorge, K. Drug, Alcohol, Medical, and Mental Health Services Desired and Received in NTIES. NEDS Fact Sheet 43. Fairfax, VA: National Evaluation Data Services, 2000.
Karageorge, K. Treatment Benefits the Mental Health of Adolescents, Young Adults, and Adults. NEDS Fact Sheet 78. Fairfax, VA: National Evaluation Data Services, 2001.
Karageorge, K. Mental Health Status of Male and Female Clients Before and After Substance Abuse Treatment. NEDS Fact Sheet 135. Fairfax, VA: National Evaluation Data Services, 2002.
Kasl, C.D. Many Roads, One Journey: Moving Beyond the Twelve Steps. New York: Harper Perennial, 1992.
Katz DA, Muehlenbruch DR, Brown RB, Fiore MC, Baker TB. (2002). Effectiveness of a clinic-based strategy for implementing the AHRQ Smoking Cessation Guideline in primary care. Preventive Medicine.
Kavanagh DJ, Young R, Boyce L, Clair A, Sitharthan T, Clark D, Thompson K. (1998). Substance Treatment Options in Psychosis (STOP): A new intervention for dual diagnosis. Journal of Mental Health.
Kelly C, McCreadie RG. (1999). Smoking habits, current symptoms, and premorbid characteristics of schizophrenic patients in Nithsdale, Scotland. American Journal of Psychiatry.
Kendler KS, MacLean C, Neale M, Kessler R, Heath A, Eaves L. (1991). The genetic epidemiology of bulimia nervosa. American Journal of Psychiatry.
Kennard D, Wilson S. (1979). The modification of personality disturbances in a therapeutic community for drug abusers. British Journal of Medical Psychology.
Kessler RC. (2003). The epidemiology of women and depression. Journal of Affective Disorders.
Kessler, R.C., Aguilar-Gaxiola, S., Andrade, L., Bijl, R., Borges, G., Caraveo-Anduaga, J.J., DeWit, D.J., Kolody, B., Merikangas, K.R., Molnar, B.E., Vega, W.A., Walters, E.E., and Wittchen, H.-U. Cross-national comparisons of comorbidities between substance use disorders and mental disorders: Results from the International Consortium in Psychiatric Epidemiology. In: Bukoski, W.J., and Sloboda, Z. (eds.). Handbook for Drug Abuse Prevention Theory, Science, and Practice. New York: Plenum Publishing Corporation, 2003a.
Kessler RC, Berglund P, Demler O, Jin R, Koretz D, Merikangas KR, Rush AJ, Walters EE, Wang PS. (2003b). The epidemiology of major depressive disorder: Results from the National Comorbidity Survey Replication (NCS-R). JAMA.
Kessler RC, Crum RM, Warner LA, Nelson CB, Schulenberg J, Anthony JC. (1997). Lifetime co-occurrence of DSM-III-R alcohol abuse and dependence with other psychiatric disorders in the National Comorbidity Survey. Archives of General Psychiatry.
Kessler RC, McGonagle K, Zhao S, Nelson CD, Hughes M, Eshleman S, Wittchen H, Kendler K. (1994). Lifetime and 12-month prevalence of DSM-III-R psychiatric disorders in the United States: Results from the National Comorbidity Survey. Archives of General Psychiatry.
Kessler RC, Nelson C, McGonagle K. (1996a). The epidemiology of co-occurring addictive and mental disorders: Implications for prevention and service utilization. American Journal of Orthopsychiatry.
Kessler, R.C., Nelson, C.B., McGonagle, K.A., Liu, J., Swartz, M., and Blazer, D.G. Comorbidity of DSM-III-R major depressive disorder in the general population: Results from the US National Comorbidity Survey. British Journal of Psychiatry. Supplement (30):17–30, 1996b.
Kessler RC, Sonnega A, Bromet E, Hughes M, Nelson CB. (1995). Posttraumatic stress disorder in the national comorbidity survey. Archives of General Psychiatry.
Kessler, R.C., and Walters, E.E. The National Comorbidity Survey. In: Tsaung, M.T., and Tohen, M., eds. Textbook in Psychiatric Epidemiology, 2d ed. New York: John Wiley & Sons, 2002. pp. 343–362.
Khantzian EJ. (1997). The self-medication hypothesis of substance use disorders: A reconsideration and recent applications. Harvard Review of Psychiatry.
Kilpatrick DG, Acierno R, Resnick HS, Saunders BE, Best CL. (1997). A 2-year longitudinal analysis of the relationships between violent assault and substance use in women. Journal of Consulting and Clinical Psychology.
Kim S, Grant JE, Adson DE, Shin YC. (2001). Double-blind naltrexone and placebo comparison study in the treatment of pathological gambling. Biological Psychiatry.
Kim, S., McLeod, J.H., and Shantzis, C. Cultural competence for evaluators working with Asian-American communities: Some practical considerations. In: Orlandi, M.A., Weston, R., and Epstein, L.G., eds. Cultural Competence for Evaluators: A Guide for Alcohol and Other Drug Abuse Prevention Practitioners Working with Ethnic/Racial Communities. OSAP Cultural Competence Series I. DHHS Publication No. (ADM) 92-1884. Rockville, MD: Office for Substance Abuse Prevention, 1992. pp. 203–260.
King MB. (1986). Eating disorders in general practice. British Medical Journal (Clinical Research Ed.).
King MB. (1989). Eating disorders in a general practice population: Prevalence, characteristics and follow-up at 12 to 18 months. Psychological Medicine Monograph Supplement.
King VL, Brooner RK, Kidorf MS, Stoller KB, Mirsky AF. (1999). Attention deficit hyperactivity disorder and treatment outcome in opioid abusers entering treatment. Journal of Nervous and Mental Disease.
Kirchner JE, Owen RR, Nordquist C, Fischer EP. (1998). Diagnosis and management of substance use disorders among inpatients with schizophrenia. Psychiatric Services.
Kleger, R.J., Brom, D., and Defares, P.B. Coping With Trauma: Theory, Prevention and Treatment. Lisse, The Netherlands: Swetz & Zeitlinger, 1992.
Kleinsasser, L.D., and Michaud, J.T. “Identifying and tracking seriously mentally ill offenders in the Colorado Department of Corrections.” Presentation to the Mental Health in Corrections Consortium, Kansas City, MO, May 2002.
Klitzner, M., and Zweig, J. Clinical Practice Guidelines and Their Dissemination: A Review and Synthesis. Chevy Chase, MD: The CDM Group, Inc., 1999.
Knight JR, Goodman E, Pulerwitz T, DuRant RH. (2000). Adolescent health issues: Reliability of short substance abuse screening tests among adolescent medical patients. Pediatrics.
Knight K, Hiller ML, Broome KM, Simpson DD. (2000). Legal pressure, treatment readiness, and engagement in long-term residential programs. Journal of Offender Rehabilitation.
Knight K, Simpson DD, Chatham LR, Camacho LM. (1997). Assessment of prison-based drug treatment: Texas' in-prison therapeutic community program. Journal of Offender Rehabilitation.
Knight K, Simpson DD, Hiller ML. (1999). Three-year reincarceration outcomes for in-prison therapeutic community treatment in Texas. The Prison Journal.
Kochanek, K.D., and Smith, B.L. Deaths: Preliminary data for 2002. National Vital Statistics Reports, Vol. 52, No. 13. Hyattsville, MD: National Center for Health Statistics. 2004. www.cdc.gov/nchs/data/nvsr/nvsr52/nvsr52_13.pdf[Accessed April 12, 2004].
Kofoed L, Friedman MJ, Peck R. (1993). Alcoholism and drug abuse in patients with PTSD. Psychiatric Quarterly.
Kozlowski LT, Porter CQ, Orleans CT, Pope MA, Heatherton T. (1994). Predicting smoking cessation with self-reported measures of nicotine dependence: FTQ, FTND, and HSI. Drug and Alcohol Dependence.
Kraft MK, Rothbard AB, Hadley TR, McLellan AT, Asch DA. (1997). Are supplementary services provided during methadone maintenance really cost-effective?. American Journal of Psychiatry.
Krejci J, Foulds J. (2003). Engaging clients in tobacco dependence treatment: Assessment and motivational techniques. Psychiatric Annals.
Krejci J, Steinberg ML, Ziedonis D. (2003). Smoking status and substance abuse severity in a residential treatment sample. Drug and Alcohol Dependence.
Kressel D, De Leon G, Palij M, Rubin G. (2000). Measuring client clinical progress in therapeutic community treatment: The therapeutic community Client Assessment Inventory, Client Assessment Summary, and Staff Assessment Summary. Journal of Substance Abuse Treatment.
Kumar R, Marks M, Wieck A, Hirst D, Campbell I, Checkley S. (1993). Neuroendocrine and psychosocial mechanisms in post-partum psychosis. Progress in Neuropsychopharmacology and Biological Psychiatry.
Kuhnz W, Koch S, Helge H, Nau H. (1988). Primidone and phenobarbital during lactation period in epileptic women: Total and free drug serum levels in the nursed infants and their effects on neonatal behavior. Developmental Pharmacology and Therapeutics.
Lacey JH. (1993). Self-damaging and addictive behaviour in bulimia nervosa: A catchment area study. British Journal of Psychiatry.
Lacey JH, Evans CD. (1986). The impulsivist: A multi-impulsive personality disorder. British Journal of Addiction.
Lacey JH, Moureli E. (1986). Bulimic alcoholics: Some features of a clinical sub-group. British Journal of Addiction.
Ladouceur, R., and Walker, M. The cognitive approach to understanding and treating pathological gambling. In: Bellack, A.S., and Herson, M., eds. Comprehensive Clinical Psychology. New York: Pergamon, 1998. pp. 588–601.
Lam JA, Rosenheck R. (1999). Street outreach for homeless persons with serious mental illness: Is it effective?. Medical Care.
Lamb, S.J., Greenlick, M.R., and McCarty, D., eds. Bridging the Gap Between Practice and Research: Forging Partnerships With Community-Based Drug and Alcohol Treatment. Washington, DC: National Academy Press, 1998.
Landry MJ, Smith DE, McDuff DR, Baughman OL. (1991a). Anxiety and substance use disorders: The treatment of high-risk patients. Journal of the American Board of Family Practice.
Landry MJ, Smith DE, Steinberg JR. (1991b). Anxiety, depression, and substance use disorders: Diagnosis, treatment, and prescribing practices. Journal of Psychoactive Drugs.
Langenbucher J, Bavly L, Labouvie E, Sanjuan PM, Martin CS. (2001). Clinical features of pathological gambling in an addictions treatment cohort. Psychology of Addictive Behaviors.
Lasser K, Boyd JW, Woolhandler S, Himmelstein DU, McCormick D. (2000). Smoking and mental illness: A population-based prevalence study. JAMA.
Laudet AB, Magura S, Vogel HS, Knight E. (2000). Recovery challenges among dually diagnosed individuals. Journal of Substance Abuse Treatment.
Le AD, Corrigall WA, Harding JWS, Juzytsch W, Li TK. (2000). Involvement of nicotinic receptors in alcohol self-administration. Alcoholism: Clinical and Experimental Research.
Leaf PJ, Thompson KS, Lam JA, Jekel JF, Armand ET, Evans AE, Martinez JS, Rodriguez C, Westman WC, Johnston P, Rowe M, Hartwell S, Blue H, Harp T. (1993). Partnerships in recovery: Shelter-based services for homeless cocaine abusers. New Haven. Alcoholism Treatment Quarterly.
Lehman, A.F., and Dixon, L.B., eds. Double Jeopardy: Chronic Mental Illness and Substance Use Disorders. Chur, Switzerland: Harwood Academic Publishers, 1995.
Lehman AF, Steinwachs DM. (1998). Patterns of usual care for schizophrenia: Initial results from the Schizophrenia Patient Outcomes Research Team (PORT) Client Survey. Schizophrenia Bulletin.
Lesieur HR, Blume SB. (1987). The South Oaks Gambling Screen (SOGS): A new instrument for the identification of pathological gamblers. American Journal of Psychiatry.
Lesieur HR, Blume SB. (1991). Evaluation of patients treated for pathological gambling in a combined alcohol, substance abuse and pathological gambling treatment unit using the Addiction Severity Index. British Journal of Addiction.
Lesieur HR, Blume S, Zoppa R. (1986). Alcoholism, drug abuse and gambling. Alcoholism: Clinical and Experimental Research.
Lesieur HR, Rosenthal RJ. (1991). Pathological gambling: A review of the literature. Prepared for the American Psychiatric Association Task Force on DSM-IV Committee on Disorders of Impulse Control Not Elsewhere Classified. Journal of Gambling Studies.
Leskin G, Ruzek J, Friedman M, Gusman F. (1999). Effective clinical management of PTSD in primary care settings: Screening and treatment options. Primary Care Psychiatry.
Levin, F.R., and Donovan, S.J. Attention-deficit/hyperactivity disorder, intermittent explosive disorder and eating disorders. In: Graham, A.W., Schultz, T.K., and Wilford, B.B., eds. Principles of Addiction Medicine. 2d ed. Chevy Chase, MD: American Society of Addiction Medicine, 1998. pp. 1029–1046.
Levin FR, Evans SM. (2001). Diagnostic and treatment issues in comorbid substance abuse and adult attention-deficit hyperactivity disorder. Psychiatric Annals.
Levin FR, Evans SM, Kleber HD. (1998). Prevalence of adult attention-deficit hyperactivity disorder among cocaine abusers seeking treatment. Drug and Alcohol Dependence.
Levinson I, Galynker II, Rosenthal RN. (1995). Methadone withdrawal psychosis. Journal of Clinical Psychiatry.
Ley, A., Jeffery, D.P., McLaren, S., and Siegfried, N. Treatment programmes for people with both severe mental illness and substance misuse. Cochrane Database System Review (4):CD001–088, 2000.
Linehan MM, Schmidt H, Dimeff LA, Craft JC, Kanter J, Comtois KA. (1999). Dialectical behavior therapy for patients with borderline personality disorder and drug-dependence. American Journal on Addictions.
Lovejoy DW, Diefenbach GJ, Licht DJ, Tolin DF. (2004). Tracking levels of psychiatric distress associated with the terrorist events of September 11, 2001: A review of the literature. Journal of Insurance Medicine.
Luborsky, L., Barber, J.P., Siqueland, L., McLellan, A.T., and Woody, G. Establishing a therapeutic alliance with substance abusers. In: Onken, L.S., Blaine, J.D., and Boren, J.J., eds. Beyond the Therapeutic Alliance: Keeping the Drug Dependent Individual in Treatment. NIDA Research Monograph 165. NIH Publication No. 97-4142. Rockville, MD: National Institute on Drug Abuse, 1997. pp. 233–244.
Luborsky L, McLellan AT, Woody GE, O'Brien CP, Auerbach A. (1985). Therapist success and its determinants. Archives of General Psychiatry.
Lucas AR, Beard CM, O'Fallon WM, Kurland LT. (1991). 50-year trends in the incidence of anorexia nervosa in Rochester, Minn: A population-based study. American Journal of Psychiatry.
Magura S, Laudet A, Mahmood D, Rosenblum A, Knight E. (2002). Adherence to medication regimens and participation in dual-focus self-help groups. Psychiatric Services.
Magura S, Laudet A, Mahmood D, Rosenblum A, Vogel H, Knight E. (2003). Role of self-help processes on achieving abstinence among dually diagnosed persons. Addictive Behaviors.
Magura S, Nwakeze PC, Demsky SY. (1998). Pre- and in-treatment predictors of retention in methadone treatment using survival analysis. Addiction.
Maisto SA, Carey KB, Carey MP, Purnine DM, Barnes KL. (1999). Methods of changing patterns of substance use among individuals with co-occurring schizophrenia and substance use disorder. Journal of Substance Abuse Treatment.
Makimoto K. (1998). Drinking patterns and drinking problems among Asian-Americans and Pacific Islanders. Alcohol Health and Research World.
Mangweth B, Hausmann A, Walch T, Hotter A, Rupp CI, Biebl W, Hudson JI, Pope HGJ. (2004). Body fat perception in eating-disordered men. International Journal of Eating Disorders.
Marks, M.N., Wieck, A., Checkley, S.A., and Kumar, R. Life stress and post-partum psychosis: A preliminary report. British Journal of Psychiatric Supplement May(10):45–49, 1991.
Marlatt, G.A. Relapse prevention: Theoretical rationale and overview of the model. In: Marlatt, G.A., and Gordon, J.R., eds. Relapse Prevention: Maintenance Strategies in the Treatment of Addictive Behaviors. New York: Guilford Press, 1985. pp. 3–70.
Marlatt, G.A., Barrett, K., and Daley, D.C. Relapse prevention. In: Galanter, M. and Kleber, H.D., eds. Textbook of Substance Abuse Treatment, 2d ed. Washington, DC: American Psychiatric Press, 1999. pp. 353–366.
Marlatt, G.A., and Gordon, J.R., eds. Relapse Prevention: Maintenance Strategies in the Treatment of Addictive Behaviors. New York: Guilford Press, 1985.
Martin SS, Butzin CA, Saum CA, Inciardi JA. (1999). Three-year outcomes of therapeutic community treatment for drug-involved offenders in Delaware: From prison to work release to aftercare. The Prison Journal.
Martin JE, Calfas KJ, Patten CA, Polarek M, Hofstetter CR, Noto J, Beach D. (1997). Prospective evaluation of three smoking interventions in 205 recovering alcoholics: One-year results of Project SCRAP-Tobacco. Journal of Consulting and Clinical Psychology.
Martino S, Carroll KM, O'Malley SS, Rounsaville BJ. (2000). Motivational interviewing with psychiatrically ill substance abusing patients. American Journal on Addictions.
Massachusetts Council on Compulsive Gambling, The Massachusetts Department of Public Health, and The Division on Addictions at Harvard Medical School. “The results of a national think tank on state-funded gambling treatment programs: A Massachusetts initiative.” Unpublished manuscript.
Mayfield D, McLeod G, Hall P. (1974). The CAGE questionnaire: Validation of a new alcoholism instrument. American Journal of Psychiatry.
Maynard C, Cox GB. (1998). Psychiatric hospitalization of persons with dual diagnoses: Estimates from two national surveys. Psychiatric Services.
McAlpine C, Marshall CC, Doran NH. (2001). Combining child welfare and substance abuse services: A blended model of intervention. Child Welfare.
McAuliffe WE, Albert J, Cordill-London G, McGarraghy TK. (1990). Contributions to a social conditioning model of cocaine recovery. International Journal of the Addictions.
McCarthy, B.R., and McCarthy, B.J. Community-based Corrections, 3d ed. Belmont, CA: Wadsworth Publishing Company, 1997.
McConnaughy EA, Prochaska J, Velicer WF. (1983). Stages of change in psychotherapy: Measurement and sample profiles. Psychotherapy: Theory, Research, and Practice.
McCorkle R, Young K. (1978). Development of a symptom distress scale. Cancer Nursing.
McCormick RA. (1993). Disinhibition and negative affectivity in substance abusers with and without a gambling problem. Addictive Behaviors.
McElhatton, P. Heart and circulatory system drugs. In: Schaefer, C. Drugs During Pregnancy and Lactation: Handbook of Prescription Drugs and Comparative Risk Assessment. Amsterdam: Elsevier Science B.V., 2001. pp. 116–131.
McElroy SL, Arnold LM, Shapira NA, Keck PEJ, Rosenthal NR, Karim MR, Kamin M, Hudson JI. (2003). Topiramate in the treatment of binge eating disorder associated with obesity: A randomized, placebo-controlled trial. American Journal of Psychiatry.
McGeary KA, French MT, Sacks S, McKendrick K, De Leon G. (2000). Service use and cost by mentally ill chemical abusers: Differences by retention in a therapeutic community. Journal of Substance Abuse.
McHugo GJ, Drake RE, Burton HL, Ackerson TH. (1995). A scale for assessing the stage of substance abuse treatment in persons with severe mental illness. Journal of Nervous and Mental Disease.
McHugo GJ, Drake RE, Teague GB, Xie H. (1999). Fidelity to assertive community treatment. Psychiatric Services.
McLellan AT, Arndt IO, Metzger DS, Woody GE, O'Brien CP. (1993). The effects of psychosocial services in substance abuse treatment. Journal of the American Medical Association.
McLellan AT, Druley KA. (1977). Non-random relation between drugs of abuse and psychiatric diagnosis. Journal of Psychiatric Research.
McLellan AT, Grissom GR, Zanis D, Randall M, Brill P, O'Brien CP. (1997). Problem-service “matching” in addiction treatment: A prospective study in 4 programs. Archives of General Psychiatry.
McLellan AT, Kushner H, Metzger D, Peters R, Smith I, Grissom G, Pettnati H, Argeriou M. (1992). The fifth edition of the Addiction Severity Index. Journal of Substance Abuse Treatment.
McLellan AT, Luborsky L, Cacciola J, Griffith J, Evans F, Barr HL, O'Brien CP. (1985). New data from the Addiction Severity Index: Reliability and validity in three centers. Journal of Nervous and Mental Disease.
McLellan AT, Luborsky L, Woody GE, O'Brien CP, Druley KA. (1983). Predicting response to alcohol and drug abuse treatment: Role of psychiatric severity. Archives of General Psychiatry.
Meadows GN, Palmer RL, Newball EU, Kenrick JM. (1986). Eating attitudes and disorder in young women: A general practice based survey. Psychological Medicine.
Mechanic D. (1987). Evolution of mental health services and areas for change. New Directions for Mental Health Services.
Mee-Lee, D. Use of patient placement criteria in the selection of treatment. In: Graham, A.W., Schultz, T.K., and Wilford, B.B., eds. Principles of Addiction Medicine. 2d ed. Chevy Chase, MD: American Society of Addiction Medicine, 1998. pp. 363–370.
Mee-Lee, D., Shulman, G.D., Fishman, M., Gastfriend, D.R., and Griffith, J.H., eds. ASAM Patient Placement Criteria for the Treatment of Substance-Related Disorders, Second Edition-Revised (ASAM PPC2R). Chevy Chase, MD: American Society of Addiction Medicine, Inc., 2001.
Meisler, A.W. Group treatment of PTSD and comorbid alcohol abuse. In: Young, B.H., and Blake, D.D., eds. Group Treatments for Post-traumatic Stress Disorder. Philadelphia, PA: Brunner/Mazel, Inc., 1999. pp. 117–136.
Meisler N, Blankertz L, Santos AB, McKay C. (1997). Impact of assertive community treatment on homeless persons with co-occurring severe psychiatric and substance use disorders. Community Mental Health Journal.
Melnick G, De Leon G. (1999). Clarifying the nature of therapeutic community treatment: The Survey of Essential Elements Questionnaire (SEEQ). Journal of Substance Abuse Treatment.
Mendoza R, Miller BL. (1992). Neuropsychiatric disorders associated with cocaine use. Hospital and Community Psychiatry.
Menezes PR, Johnson S, Thornicroft G, Marshall J, Prosser D, Bebbington P, Kuipers E. (1996). Drug and alcohol problems among individuals with severe mental illness in south London. British Journal of Psychiatry.
Messina NP, Wish ED, Nemes S. (1999). Therapeutic community treatment for substance abusers with antisocial personality disorder. Journal of Substance Abuse Treatment.
Mid-America Addiction Technology Transfer Center. Psychotherapeutic Medications 2004: What Every Counselor Should Know. 2004. www.mattc.org[Accessed November 1, 2004].
Milberger S, Biederman J, Faraone SV, Wilens T, Chu MP. (1997). Associations between ADHD and psychoactive substance use disorders: Findings from a longitudinal study of high-risk siblings of ADHD children. American Journal on Addictions.
Milby JB, Schumacher JE, McNamara C, Wallace D, Usdan S. (2000). Initiating abstinence in cocaine abusing dually diagnosed homeless persons. Drug & Alcohol Dependence.
Milby JB, Schumacher JE, Raczynski JM, Caldwell E, Engle M, Michael M, Carr J. (1996). Sufficient conditions for effective treatment of substance abusing homeless persons. Drug and Alcohol Dependence.
Miller, D., and Guidry, L. Addictions and Trauma Recovery: Healing the Body, Mind, and Spirit. New York: W.W. Norton, 2001.
Miller, G.A. The Substance Abuse Subtle Screening Inventory (SASSI) Manual. Springville, IN: SASSI Institute, 1985.
Miller, G.A. Adult SASSI-3 Manual. Springville, IN: SASSI Institute, 2000a.
Miller, N.S. Medications used with the dually diagnosed. In: Miller, N.S., ed. Treating Coexisting Psychiatric and Addictive Disorders: A Practical Guide. Center City, MN: Hazelden, 1994a, pp. 143–160.
Miller, N.S. The interactions between coexisting disorders. In: Miller, N.S., ed. Treating Coexisting Psychiatric and Addictive Disorders: A Practical Guide. Center City, MN: Hazelden, 1994b. pp. 7–21.
Miller, N.S., ed. Treating Coexisting Psychiatric and Addictive Disorders: A Practical Guide. Center City, MN: Hazelden, 1994c.
Miller WR. (1996). Motivational interviewing: Research, practice, and puzzles. Addictive Behaviors.
Miller WR. (2000b). Motivational interviewing: IV. Some parallels with horse whispering. Behavioural and Cognitive Psychotherapy.
Miller WR, Benefield RG, Tonigan JS. (1993). Enhancing motivation for change in problem drinking: A controlled comparison of two therapist styles. Journal of Consulting and Clinical Psychology.
Miller WR, Brown SA. (1997). Why psychologists should treat alcohol and drug problems. American Psychologist.
Miller, W.R., and Rollnick, S. Motivational Interviewing: Preparing People to Change Addictive Behavior. New York: Guilford Press, 1991.
Miller, W.R., and Rollnick, S. Motivational Interviewing: Preparing People for Change. 2d ed. New York: Guilford Press, 2002.
Miller WR, Taylor CA, West J. (1980). Focused versus broad-spectrum behavior therapy for problem drinkers. Journal of Consulting and Clinical Psychology.
Miller WR, Tonigan JS. (1996). Assessing drinkers' motivations for change: The Stages of Change Readiness and Treatment Eagerness Scale (SOCRATES). Psychology of Addictive Behavior.
Miller, W.R., Zweben, A., DiClemente, C.C., and Rychtarik, R.G. Motivational Enhancement Therapy Manual: A Clinical Research Guide for Therapists Treating Individuals With Alcohol Abuse and Dependence. Project MATCH Monograph Series Vol. 2. Rockville, MD: National Institute on Alcohol Abuse and Alcoholism, 1992.
Milmoe S, Rosenthal R, Blane HT, Chafetz ME, Wolf I. (1967). The doctor's voice: Postdictor of successful referral of alcoholic patients. Journal of Abnormal Psychology.
Minkoff K. (1989). An integrated treatment model for dual diagnosis of psychosis and addiction. Hospital and Community Psychiatry.
Minkoff, K. Model for the Desired Array of Services and Clinical Competencies for a Comprehensive, Continuous, Integrated System of Care. Worcester, MA: University of Massachusetts, Department of Psychiatry, Center for Mental Health Services Research, 1999.
Minkoff K. (2001a). Developing standards of care for individuals with co-occurring psychiatric and substance use disorders. Psychiatric Services.
Minkoff, K. MIDAS: Mental illness drug and alcohol screening tool. 2001b. Unpublished. www.kenminkoff.com.
Minkoff, K., and Cline, C. COMPASS (Version 1.0): Comorbidity Program Audit and Self-Survey for Behavioral Health Services. Adult and Adolescent Program Audit Tool for Dual Diagnosis Capability. Co-Occurring Disorders Services Enhancement Toolkit - Tool Number 5. Albuquerque, NM: Zialogic, 2001a.
Minkoff, K., and Cline, C. The New Mexico Train the Trainers Curriculum. Santa Fe, NM: New Mexico Department of Health, Behavioral Health Services Division, 2001b.
Minkoff, K., and Drake, R., eds. Dual Diagnosis of Major Mental Illness and Substance Disorder. San Francisco: Jossey-Bass, 1991.
Mitchell JE, Boutacoff LI, Hatsukami D, Pyle RL, Eckert ED. (1986). Laxative abuse as a variant of bulimia. Journal of Nervous and Mental Disease.
Mitchell JE, Hatsukami D, Eckert ED, Pyle RL. (1985). Characteristics of 275 patients with bulimia. American Journal of Psychiatry.
Mitchell JE, Pyle R, Eckert ED, Hatsukami D. (1990). The influence of prior alcohol and drug abuse problems on bulimia nervosa treatment outcome. Addictive Behaviors.
Monti PM, Rohsenow DJ, Rubonis AV, Niaura RS, Sirota AD, Colby SM, Goddard P, Abrams DB. (1993). Cue exposure with coping skills treatment for male alcoholics: A preliminary investigation. Journal of Consulting and Clinical Psychology.
Moolchan ET, Radzius A, Epstein DH, Uhl G. (2002). The Fagerstrom Test for Nicotine Dependence and the Diagnostic Interview Schedule: Do they diagnose the same smokers?. Addictive Behaviors.
Moore, G.E., and Mears, D.P. Voices from the Field: Practitioners Identify Key Issues in Corrections-Based Drug Treatment. Washington, DC: The Urban Institute, 2003. www.urban.org/url.cfm?ID=410617 [Accessed November 26, 2004]
Moos, R.H. Coping Responses Inventory: Adult Form. Professional Manual. Odessa, FL: Psychological Assessment Resources, 1993.
Moos RH, Finney JW, Federman EB, Suchinsky R. (2000). Specialty mental health care improves patients' outcomes: Findings from a nationwide program to monitor the quality of care for patients with substance use disorders. Journal of Studies on Alcohol.
Morgan HG, Purgold J, Welbourne J. (1983). Management and outcome in anorexia nervosa: A standardized prognostic study. British Journal of Psychiatry.
Morrissey J, Calloway M, Johnsen M, Ullman M. (1997). Service system performance and integration: A baseline profile of the ACCESS demonstration sites. Access to Community Care and Effective Services and Supports. Psychiatric Services.
Morse GA, Calsyn RJ, Allen G, Tempelhoff B, Smith R. (1992). Experimental comparison of the effects of three treatment programs for homeless mentally ill people. Hospital and Community Psychiatry.
Morse GA, Calsyn RJ, Klinkenberg WD, Trusty ML, Gerber F, Smith R, Tempelhoff B, Ahmad L. (1997). An experimental comparison of three types of case management for homeless mentally ill persons. Psychiatric Services.
Moser AE, Annis HM. (1996). The role of coping in relapse crisis outcome: A prospective study of treated alcoholics. Addiction.
Mortola JF. (1989). The use of psychotropic agents in pregnancy and lactation. Psychiatric Clinics of North America.
Mueser, K.T., Bennett, M., and Kushner, M.G. Epidemiology of substance use disorders among persons with chronic mental illnesses. In: Lehman, A.F., and Dixon, L.B., eds. Double Jeopardy: Chronic Mental Illness and Substance Use Disorders. Chur, Switzerland: Harwood Academic Publishers, 1995a. pp. 9–25.
Mueser KT, Bond GR, Drake RE, Resnick SG. (1998). Models of community care for severe mental illness: A review of research on case management. Schizophrenia Bulletin.
Mueser, K.T., Drake, R.E., Clark, R.E., McHugo, G.J., Mercer-McFadden, C., and Ackerson, T.H. Toolkit for Evaluating Substance Abuse in Persons with Severe Mental Illness. Cambridge, MA: Evaluation Center, Human Services Research Institute, 1995b.
Mueser, K.T., Drake, R.E., and Miles, K.M. The course and treatment of substance use disorder in persons with severe mental illness. In: Onken, L.S., Blaine, J.D., Genser, S., and Horton, A.M., eds. Treatment of Drug-Dependent Individuals With Comorbid Mental Disorders. NIDA Research Monograph 172. NIH Publication No. 97-4172. Rockville, MD: National Institute on Drug Abuse, 1997. pp. 86–109.
Mueser KT, Yarnold PR, Bellack AS. (1992). Diagnostic and demographic correlates of substance abuse in schizophrenia and major affective disorder. Acta Psychiatrica Scandinavica.
Mueser KT, Yarnold PR, Levinson DF, Singh H, Bellack AS, Kee K, Morrison RL, Yadalam KG. (1990). Prevalence of substance abuse in schizophrenia: Demographic and clinical correlates. Schizophrenia Bulletin.
Mueser KT, Yarnold PR, Rosenberg SD, Swett C, Miles KM, Hill D. (2000). Substance use disorder in hospitalized severely mentally ill psychiatric patients: Prevalence, correlates, and subgroups. Schizophrenia Bulletin.
Murphy GE, Wetzel RD. (1990). Lifetime risk of suicide in alcoholism. Archives of General Psychiatry.
Nace EP. (1990). Substance abuse and personality disorder. Journal of Chemical Dependency.
Nadeau L, Landry M, Racine S. (1999). Prevalence of personality disorders among clients in treatment for addiction. Canadian Journal of Psychiatry.
Najavits LM. (2000). Training clinicians in the Seeking Safety treatment protocol for posttraumatic stress disorder and substance abuse. Alcoholism Treatment Quarterly.
Najavits, L.M. Seeking Safety: A Treatment Manual for PTSD and Substance Abuse. New York: Guilford Press, 2002.
Najavits LM, Crits-Christoph P, Dierberger A. (2000). Clinicians' impact on the quality of substance use disorder treatment. Substance Use and Misuse.
Najavits LM, Griffin ML, Luborsky L, Frank A, Weiss RD, Liese BS, Siqueland L, Daley D, Onken LS. (1995). Therapists' emotional reactions to substance abusers: A new questionnaire and initial findings. Psychotherapy: Theory, Research, Practice, Training.
Najavits LM, Weiss RD. (1994). Variations in therapist effectiveness in the treatment of patients with substance use disorders: An empirical review. Addiction.
Najavits LM, Weiss RD, Reif S, Gastfriend DR, Siqueland L, Barber JP, Butler SF, Thase M. (1998). The Addiction Severity Index as a screen for trauma and posttraumatic stress disorder. Journal of Studies on Alcohol.
Najavits LM, Weiss RD, Shaw SR. (1997). The link between substance abuse and posttraumatic stress disorder in women: A research review. American Journal on Addictions.
Narrow WE, Regier DA, Rae DS, Manderscheid RW, Locke BZ. (1993). Use of services by persons with mental and addictive disorders: Findings from the National Institute of Mental Health Epidemiologic Catchment Area Program. Archives of General Psychiatry.
National Advisory Council, Substance Abuse and Mental Health Services Administration. Improving Services for Individuals at Risk of, or with, Co-Occurring Substance-Related and Mental Health Disorders. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1997. www.toad.net/~arcturus/dd/peppdown.htm[Accessed December 27, 2000].
National Alliance for the Mentally Ill. Recommended PACT Standards for New Teams. Arlington, VA: National Alliance for the Mentally Ill, 1999. www.nami.org/about/pactstd.html[Accessed February 12, 2001].
National Association of State Mental Health Program Directors and National Association of State Alcohol and Drug Abuse Directors. National Dialogue on Co-Occurring Mental Health and Substance Abuse Disorders. Washington, DC: National Association of State Alcohol and Drug Abuse Directors, 1999. www.nasadad.org/Departments/Research/ConsensusFramework/national_dialogue_on.htm[Accessed December 27, 2000].
National Association of State Mental Health Program Directors and National Association of State Alcohol and Drug Abuse Directors. Financing and Marketing the New Conceptual Framework for Co-Occurring Mental Health and Substance Abuse Disorders: A Blueprint for Systems Change. Alexandria, VA: National Association of State Mental Health Program Directors and National Association of State Alcohol and Drug Abuse Directors, 2000.
National Council on Problem Gambling. “1998 National Survey of Problem Gambling Programs: Report to the National Gambling Impact Study Commission.” Unpublished manuscript.
National Institute on Alcohol Abuse and Alcoholism. Motivational Enhancement Therapy Manual. Project MATCH Series, vol 2. NIH Pub. No. 94-3723. Bethesda, MD: National Institute on Alcohol Abuse and Alcoholism, 1994.
National Institute on Drug Abuse. Consensus Statement on Evaluation of Outcome of Pharmacotherapy for Substance Abuse/Dependence, Report from a NIDA/CPDD Meeting Held in Washington, DC April 23–24, 1999. Bethesda, MD: National Institute on Drug Abuse, 1999b. www.atforum.com/SiteRoot/pages/addiction_resources/Addcn%20Pharm%20Goals.pdf[Accessed June 16, 2004].
National Institute on Drug Abuse. How Good Is Your Drug Abuse Treatment Program? A Guide to Evaluation. Rockville, MD: National Institutes of Health, 1993.
National Institute on Drug Abuse. Mental Health Assessment and Diagnosis of Substance Abusers. Clinical Report Series. NIH Publication No. 94-3846. Bethesda, MD: National Institutes of Health, 1994.
National Institute on Drug Abuse. Principles of Drug Addiction Treatment: A Research-Based Guide. NIH Publication No. 00-4180. Bethesda, MD: National Institutes of Health, 1999.
National Institute on Drug Abuse. Recovery Training and Self Help: Relapse Prevention and Aftercare for Drug Addicts. NIH Publication No. 93-3521. Rockville, MD: National Institute on Drug Abuse, 1993.
National Law Center on Homelessness and Poverty. Out of Sight—Out of Mind? A Report on Anti-Homeless Laws, Litigation, and Alternatives in 50 United States Cities. Washington, DC: National Law Center on Homelessness and Poverty, 1999.
National Research Council, Committee on the Social and Economic Impact of Pathological Gambling, and Committee on Law and Justice. Pathological Gambling: A Critical Review. Washington, DC: National Academy Press, 1999.
Nelson CB, Heath AC, Kessler RC. (1998). Temporal progression of alcohol dependence symptoms in the U.S. household population: Results from the National Comorbidity Survey. Journal of Consulting and Clinical Psychology.
Nielsen Forman D, Videbech P, Hedegaard M, Dalby SJ, Secher NJ. (2000). Postpartum depression: Identification of women at risk. BJOG: An International Journal of Obstetrics and Gynaecology.
Nigam R, Schottenfeld R, Kosten TR. (1992). Treatment of dual diagnosis patients: A relapse prevention group approach. Journal of Substance Abuse Treatment.
Nilsson A, Waller L, Rosengren A, Adlerberth A, Wilhelmsen L. (1997). Cigarette smoking is associated with abnormal involuntary movements in the general male population—a study of men born in 1933. Biological Psychiatry.
Nishith P, Duntley SP, Domitrovich PP, Uhles ML, Cook BJ, Stein PK. (2003). Effect of cognitive behavioral therapy on heart rate variability during REM sleep in female rape victims with PTSD. Journal of Traumatic Stress.
Noordsy, D.L, and Drake, R.E. Case management. In: Miller, N.S., ed. Treating Coexisting Psychiatric and Addictive Disorders: A Practical Guide. Center City, MN: Hazelden, 1994. pp. 231–244.
North CS, Eyrich KM, Pollio DE, Spitznagel EL. (2004). Are rates of psychiatric disorders changing over time in the homeless population?. American Journal of Public Health.
Oates M. (1989). Management of major mental illness in pregnancy and the puerperium. Baillieres Best Practice and Research: Clinical Obstetrics and Gynaecology.
O'Brien, R.W., Johnson, J., and Rickards, L.D. Insights and Inroads: Project Highlights of the CMHS and CSAT Collaborative Demonstration Program for Homeless Individuals. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000.
Ochberg FM. (1996). The counting method for ameliorating traumatic memories. Journal of Traumatic Stress.
O'Connell, D.F. Dual Disorders: Essentials for Assessment and Treatment. New York: Haworth Press, 1998.
Office of Applied Studies. Substance Abuse and Mental Health Statistics Sourcebook. Analytic Series A-4. DHHS Publication No. (SMA) 98-3170. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998.
Office of Applied Studies. Uniform Facility Data Set (UFDS): 1999. Data on Substance Abuse Treatment Facilities. DASIS Series S-13. DHHS Publication No. (SMA) 01-3516. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001.
Office of Applied Studies. National Survey of Substance Abuse Treatment Services (N-SSATS): 2002—Data on Substance Abuse Treatment Facilities. DASIS Series S-19, DHHS Publication No. (SMA) 03-3777. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2003a.
Office of Applied Studies. Results from the 2002 National Survey on Drug Use and Health: National Findings. NHSDA Series H-22, DHHS Publication No. (SMA) 03-3836. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2003b.
Office of Applied Studies. Overview of Findings from the 2003 National Survey on Drug Use and Health. NSDUH Series H-24, DHHS Publication No. (SMA) 04-3963. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2003c. www.oas.samhsa.gov/nhsda/2k3nsduh/2k3Overview.htm[Accessed December 1, 2004].
Office of National Drug Control Policy. National Drug Control Strategy: Strengthening Communities' Response to Drugs and Crime. Washington, DC: Office of National Drug Control Policy, 1995. www.ncjrs.org/pdffiles/strat95b.pdf[Accessed March 18, 2002].
Office of the Inspector General, Department of Health and Human Services. Services to Persons with Co-Occurring Mental Health and Substance Abuse Disorders. OEI-05-94-00151. Washington, DC: Department of Health and Human Services, 1995.
Office of the Surgeon General. Mental Health: A Report of the Surgeon General. Rockville, MD: U.S. Public Health Service, 1999. www.surgeongeneral.gov/library/mentalhealth/home.html[Accessed March 18, 2002].
O'Hara MW, Stuart S, Gorman LL, Wenzel A. (2000). Efficacy of interpersonal psychotherapy for postpartum depression. Archives of General Psychiatry.
Olincy A, Young DA, Freedman R. (1997). Increased levels of the nicotine metabolite cotinine in schizophrenic smokers compared to other smokers. Biological Psychiatry.
Onken, L.S., Blaine, J., Genser, S., and Horton, A.M., eds. Treatment of Drug-Dependent Individuals with Comorbid Mental Disorders. NIDA Research Monograph 172. NIH Publication No. 97-4172. Rockville, MD: National Institute on Drug Abuse, 1997.
Ormont LR. (1999). Establishing transient identification in the group setting. Modern Psychoanalysis.
Osher FC, Drake RE. (1996). Reversing a history of unmet needs: Approaches to care for persons with co-occurring addictive and mental disorders. American Journal of Orthopsychiatry.
Osher FC, Kofoed LL. (1989). Treatment of patients with psychiatric and psychoactive substance abuse disorders. Hospital and Community Psychiatry.
Ouimette PC, Ahrens C, Moos RH, Finney JW. (1998). During treatment changes in substance abuse patients with posttraumatic stress disorder: The influence of specific interventions and program environments. Journal of Substance Abuse Treatment.
Ouimette PC, Finney JW, Moos RH. (1999). Two-year posttreatment functioning and coping of substance abuse patients with posttraumatic stress disorder. Psychology of Addictive Behaviors.
Patten CA, Martin JE, Owen N. (1996). Can psychiatric and chemical dependency treatment units be smoke free?. Journal of Substance Abuse Treatment.
Patten CA, Martin JE, Myers MG, Calfas KJ, Williams CD. (1998). Effectiveness of cognitive-behavioral therapy for smokers with histories of alcohol dependence and depression. Journal of Studies on Alcohol.
Patten CA, Martin JE, Calfas KJ, Lento J, Wolter TD. (2001). Behavioral treatment for smokers with a history of alcoholism: Predictors of successful outcome. Journal of Consulting and Clinical Psychology.
Payne TJ, Smith PO, McCracken LM, McSherry WC, Antony MM. (1994). Assessing nicotine dependence: A comparison of the Fagerstrom Tolerance Questionnaire (FTQ) with the Fagerstrom Test for Nicotine Dependence (FTND) in a clinical sample. Addictive Behaviors.
Pepper B, Kirshner MC, Ryglewicz H. (1981). The young adult chronic patient: Overview of a population. Hospital and Community Psychiatry.
Pepper, B., and Massaro, J. Substance Abuse and Mental/Emotional Disorders: Counselor Training Manual. New York: The Information Exchange, 1995.
Pepper, B., and Ryglewicz, H. Lives at Risk: Understanding and Treating Young People With Dual Disorders. New York: Free Press, 1996. p. 200.
Perry A, Tarrier N, Morrissy R, McCarthy E, Limb K. (1999). Randomized controlled trial of efficacy of teaching patients with bipolar disorder to identify early symptoms of relapse and obtain treatment. British Medical Journal.
Perucca E, Crema A. (1982). Plasma protein binding of drugs in pregnancy. Clinical Pharmacokinetics.
Peters RH, Greenbaum PE, Steinberg ML, Carter CR. (2000). Effectiveness of screening instruments in detecting substance use disorders among prisoners. Journal of Substance Abuse Treatment.
Peters, R.H., and Hills, H.A. Inmates with co-occurring substance abuse and mental health disorders. In: Steadman, H.J., and Cocozza, J.J., eds. Mental Illness in America's Prisons. Seattle, WA: National Coalition for the Mentally Ill in the Criminal Justice System, 1993. pp. 159–212.
Peters, R.H., and Hills, H.A. Intervention Strategies for Offenders with Co-Occurring Disorders: What Works? Delmar, NY: National GAINS Center, 1997. www.prainc.com/gains/publications/intervention.htm[Accessed January 9, 2001].
Peters RH, Kearns WD, Murrin MR, Dolente AS, May RL. (1993). Examining the effectiveness of in-jail substance abuse treatment. Journal of Offender Rehabilitation.
Peters RH, LeVasseur ME, Chandler RK. (2004). Correctional treatment for co-occurring disorders: Results of a national survey. Behavioral Sciences and the Law.
Peters, R.H., and Peyton, E. Guideline for Drug Courts on Screening and Assessment. Washington, DC: Office of Justice Programs, Drug Courts Program Office, 1998. www.ojp.usdoj.gov/dcpo/gdc.pdf[Accessed April 1, 2002].
Peters, R.H., and Steinberg, M.L. Substance abuse treatment services in U.S. prisons. In: Shewan, D., and Davies, J., eds. Drug Use and Prisons. Singapore: Harwood Academic Publishers, 2000. pp. 89–116.
Petry NM. (2000a). A comprehensive guide to the application of contingency management procedures in clinical settings. Drug and Alcohol Dependence.
Petry NM. (2000b). Gambling problems in substance abusers are associated with increased sexual risk behaviors. Addiction.
Petry NM. (2000c). Psychiatric symptoms in problem gambling and non-problem gambling substance abusers. American Journal on Addictions.
Petry NM, Bickel WK. (1999). Therapeutic alliance and psychiatric severity as predictors of completion of treatment for opioid dependence. Psychiatric Services.
Petry NM, Martin B, Cooney J, Kranzier HR. (2000). Give them prizes and they will come: Contingency management for the treatment of alcohol dependence. Journal of Consulting and Clinical Psychology.
Petry NM, Martin B, Finocche C. (2001a). Contingency management in group treatment: A demonstration project in an HIV drop-in center. Journal of Substance Abuse Treatment.
Petry NM, Petrakis I, Trevisan L, Wiredu G, Boutros NN, Martin B, Kosten TR. (2001b). Contingency management interventions: From research to practice. American Journal of Psychiatry.
Peveler R, Fairburn C. (1990). Eating disorders in women who abuse alcohol. British Journal of Addiction.
Peveler RC, Fairburn CG, Boller I, Dunger D. (1992). Eating disorders in adolescents with IDDM: A controlled study. Diabetes Care.
Peyrot M. (1985). Narcotics Anonymous: Its history, structure, and approach. International Journal of the Addictions.
Piette, J., and Fong, W.X. Health Services for VA Substance Abuse and Psychiatric Patients: Comparison of Utilization in Fiscal Years 2000, 1999, and 1995. Palo Alto, CA: Veterans Affairs Health Care System, Program Evaluation and Resource Center and HSR&D Center for Health Care Evaluation, 2001.
Polonsky WH, Anderson BJ, Lohrer PA, Aponte JE, Jacobson AM, Cole CF. (1994). Insulin omission in women with IDDM. Diabetes Care.
Pond SM, Kreek MJ, Tong TG, Raghunath J, Benowitz NL. (1985). Altered methadone pharmacokinetics in methadone-maintained pregnant women. Journal of Pharmacology and Experimental Therapeutics.
Pope HG, Hudson JI, Nixon RA, Herridge PL. (1986). The epidemiology of ipecac abuse. New England Journal of Medicine.
Potenza MN. (2001). The neurobiology of pathological gambling. Seminars in Clinical Neuropsychiatry.
Poussaint, A.F., and Alexander, A. Lay My Burden Down: Unraveling Suicide and the Mental Health Crisis Among African Americans. Boston: Beacon Press, 2000.
Powell, D.J., and Brodsky, A. Clinical Supervision in Alcohol and Drug Abuse Counseling: Principles, Models, Methods. San Francisco: Jossey-Bass, 1993.
Prendergast ML, Hall EA, Wexler HK, Melnick G, Cao Y. (2004). Amity prison-based therapeutic community: 5-year outcomes. Prison Journal.
Prochaska, J.O., and DiClemente, C.C. Stages of change in the modification of problem behavior. In: Hersen, M., Eisler, R., and Miller, P.M., eds. Progress in Behavior Modification. Sycamore, IL: Sycamore Publishing Company, 1992. pp. 184–214.
Prochaska JO, DiClemente CC, Norcross JC. (1992). In search of how people change: Applications to addictive behaviors. American Psychologist.
Pyle RL, Mitchell JE, Eckert ED. (1981). Bulimia: A report of 34 cases. Journal of Clinical Psychiatry.
Quinnett, P., and Bratcher, K. Question, Persuade, Refer, Treat: Suicide Risk Management Inventory User's Manual. Spokane, WA: Greentree Behavioral Health, 1996.
Rahav M, Link BG. (1995). When social problems converge: Homeless, mentally ill, chemical misusing men in New York City. International Journal of the Addictions.
Rahav M, Rivera JJ, Nuttbrock L, Ng-Mak D, Sturz EL, Link BG, Struening EL, Pepper B, Gross B. (1995). Characteristics and treatment of homeless, mentally ill, chemical-abusing men. Journal of Psychoactive Drugs.
Raimo EB, Schuckit MA. (1998). Alcohol dependence and mood disorders. Addictive Behaviors.
Raine, A., Lencz, T., Bihrle, S., LaCasse, L., and Colletti, P. Reduced prefrontal gray matter volume and reduced autonomic activity in antisocial personality disorder. Archives of General Psychiatry 57(2):119–127; discussion 128–129, 2000.
Rand CS, Kuldau JM. (1992). Epidemiology of bulimia and symptoms in a general population: Sex, age, race, and socioeconomic status. International Journal of Eating Disorders.
Raskind MA, Peskind ER, Kanter ED, Petrie EC, Radant A, Thompson CE, Dobie DJ, Hoff D, Rein RJ, Straits-Troster K, Thomas RG, McFall MM. (2003). Reduction of nightmares and other PTSD symptoms in combat veterans by prazosin: A placebo-controlled study. American Journal of Psychiatry.
Raskind MA, Thompson C, Petrie EC, Dobie DJ, Rein RJ, Hoff DJ, McFall ME, Peskind ER. (2002). Prazosin reduces nightmares in combat veterans with posttraumatic stress disorder. Journal of Clinical Psychiatry.
Rawson RA, Obert JL, McCann MJ, Marinelli-Casey P. (1993). Relapse prevention models for substance abuse treatment. Psychotherapy.
Regier DA, Farmer ME, Rae DS, Locke BZ, Keith SJ, Judd LL, Goodwin FK. (1990). Comorbidity of mental disorders with alcohol and other drug abuse: Results from the Epidemiologic Catchment Area (ECA) study. Journal of the American Medical Association.
Reilly PM, Clark HW, Shopshire MS, Lewis EW, Sorensen DJ. (1994). Anger management and temper control: Critical components of posttraumatic stress disorder and substance abuse treatment. Journal of Psychoactive Drugs.
Research Evaluates Gambling's Impact. Melbourne, Australia: University of Melbourne, 1998. www.unimelb.edu.au/ExtRels/Media/UN/archive/1998/339/researchevaluatesgambling.html[Accessed September 11, 2002].
Richter KP, Ahluwalia JS. (2000). A case for addressing cigarette use in methadone and other opioid treatment programs. Journal of Addictive Diseases.
Richter KP, Gibson CA, Ahluwalia JS, Schmelzle KH. (2001). Tobacco use and quit attempts among methadone maintenance clients. American Journal of Public Health.
Ridgely MS, Lambert D, Goodman A, Chichester CS. (1998). Interagency collaboration in services for people with co-occurring mental illness and substance use disorder. Psychiatric Services.
Ries RK. (1993). The dually diagnosed patient with psychotic symptoms. Journal of Addictive Diseases.
Ries RK, Comtois KA. (1997). Managing disability benefits as part of treatment for persons with severe mental illness and comorbid drug/alcohol disorders: A comparative study of payee and non-payee participants. American Journal on Addictions.
Ries RK, Dyck DG. (1997). Representative payee practices of community mental health centers in Washington State. Psychiatric Services.
Ries, R.K., and Miller, N.S. Dual diagnosis: Concept, diagnosis and treatment. In: Dunner, D.L., ed. Current Psychiatric Therapy. Philadelphia: W.B. Saunders Company, 1993. pp. 131–138.
Ries R, Russo J, Wingerson D, Snowden M, Comtois KA, ebnik D, Roy-Byrne P. (2000). Shorter hospital stays and more rapid improvement among patients with schizophrenia and substance disorders. Psychiatric Services.
Riggs DS, Rukstalis M, Volpicelli JR, Kalmanson D, Foa EB. (2003). Demographic and social adjustment characteristics of patients with comorbid posttraumatic stress disorder and alcohol dependence: Potential pitfalls to PTSD treatment. Addictive Behaviors.
Ritzler BA, Strauss JS, Vanord A, Kokes RF. (1977). Prognostic implications of various drinking patterns in psychiatric patients. American Journal of Psychiatry.
Robert, E., Reuvers, M., and Shaefer, C. Antiepileptics. In: Schaefer, C.H., ed. Drugs During Pregnancy and Lactation: Handbook of Prescription Drugs and Comparative Risk Assessment: With Updated Information on Recreational Drugs. Amsterdam: Elsevier, 2001. pp. 46–57.
Roberts, L.J., Shaner, A., and Eckman, T.A. Overcoming Addictions: Skills Training for People with Schizophrenia. New York: W. W. Norton & Co., 1999.
Robson, E., Edwards, J., Smith, G., and Coleman, I. Executive Summary of the One Year Community Trial. Alberta, Canada: Capital Health Authority, Regional Public Health, 2001.
Rodin G, Craven J, Littlefield C, Murray M, Daneman D. (1991). Eating disorders and intentional insulin undertreatment in adolescent females with diabetes. Psychosomatics.
Rog, D.J., and Gutman, M. The Homeless Families Program: A summary of key findings. In: Isaacs, S.L., and Knickman, J.R. (eds.) To Improve Health and Health Care 1997: The Robert Wood Johnson Foundation Anthology. San Francisco: Jossey-Bass Publishers, 1997. pp. 209–231.
Rogers, C.R., Gendlin, E.T., Kiesler, D.T., and Traux, C.B., eds. The Therapeutic Relationship and Its Impact: A Study of Psychotherapy with Schizophrenics. Madison, WI: University of Wisconsin Press, 1967.
Rogers JR. (1992). Suicide and alcohol: Conceptualizing the relationship from a cognitive-social paradigm. Journal of Counseling and Development.
Rollnick S, Miller WR. (1995). What is motivational interviewing?. Behavioural and Cognitive Psychotherapy.
Rome ES. (2003). Eating disorders. Obstetrics and Gynecology Clinics of North America.
Root MP. (1989). Treatment failures: The role of sexual victimization in women's addictive behavior. American Journal of Orthopsychiatry.
Rosenberg SD, Drake RE, Wolford GL, Mueser KT, Oxman TE, Vidaver RM, Carrieri KL, Luckoor R. (1998). Dartmouth Assessment of Lifestyle Instrument (DALI): A substance use disorder screen for people with severe mental illness. American Journal of Psychiatry.
Rosenheck R, Morrissey J, Lam J, Calloway M, Johnsen M, Goldman H, Randolph F, Blasinsky M, Fontana A, Calsyn R, Teague G. (1998). Service system integration, access to services, and housing outcomes in a program for homeless persons with severe mental illness. American Journal of Public Health.
Rosenthal RJ. (1992). Pathological gambling. Psychiatric Annals.
Rosenthal RJ, Lesieur HR. (1992). Self-reported withdrawal symptoms and pathological gambling. American Journal on Addictions.
Rosenthal RJ, Rugle L. (1994). A psychodynamic approach to the treatment of pathological gambling: Part I. Achieving abstinence. Journal of Gambling Studies.
Rosenthal, R.N. Mental Illness/Chemical Addiction: A Guide for Emergency Services, Assessment and Treatment. New York: New York State Office of Mental Health, 1992.
Rosenthal RN, Miner CR. (1997). Differential diagnosis of substance-induced psychosis and schizophrenia in patients with substance use disorders. Schizophrenia Bulletin.
Ross HE, Glaser FB, Germanson T. (1988). The prevalence of psychiatric disorders in patients with alcohol and other drug problems. Archives of General Psychiatry.
Rossi PH. (1990). The old homeless and the new homelessness in historical perspective. American Psychologist.
Rosten, K.L. Colorado Department of Corrections Statistical Report: Fiscal Year 2000. Colorado Spring, CO: Colorado Department of Corrections, 2001. www.doc.state.co.us/Statistics/pdfs/STAT2000.pdf[Accessed February 6, 2002].
Rounsaville, B., and Caroll, K. Psychiatric disorders in treatment-entering cocaine abusers. In: Schober, S., and Schade, C., eds. Epidemiology of Cocaine Use and Abuse. NIDA Research Monograph Series, Number 110. DHHS Pub. No. (ADM) 91-1787. Rockville, MD: National Institute on Drug Abuse, 1991.
Rounsaville BJ, Tierney T, Crits-Cristoph K, Weissman MM, Kleber HD. (1982a). Predictors of outcome in treatment of opiate addicts: Evidence for the multidimensional nature of addicts' problems. Comprehensive Psychiatry.
Rounsaville, B.J., Tims, F.M., Horton, A.M., Jr., and Sowder, B.J., eds. Diagnostic Source Book on Drug Abuse Research and Treatment. NIH Publication No. 93-3508. Rockville, MD: National Institute on Drug Abuse, 1993.
Rounsaville BJ, Weissman MM, Kleber H, Wilber C. (1982b). Heterogeneity of psychiatric diagnosis in treated opiate addicts. Archives of General Psychiatry.
Rowland AS, Lesesne CA, Abramowitz AJ. (2002). The epidemiology of attention-deficit/hyperactivity disorder (ADHD): A public health view. Mental Retardation Developmental Diability Research Review.
Rugle, L. “Understanding Pathological Gamblers in Treatment.” Presented at the SAMHSA Symposium on Problem and Pathological Gambling: A Look at the Issues of Mental Health. Washington, DC, 2000.
Rugle L, Rosenthal RJ. (1994). Transference and countertransference reactions in the psychotherapy of pathological gamblers. Journal of Gambling Studies.
Rutherford MJ, Cacciola JS, Alterman AI. (1999). Antisocial personality disorder and psychopathy in cocaine-dependent women. American Journal of Psychiatry.
Ryglewicz, H., and Pepper, B. Lives at Risk: Understanding and Treating Young People with Dual Disorders. New York: Free Press, 1996.
Sacks S. (2000). Co-occurring mental and substance use disorders: Promising approaches and research issues. Substance Use and Misuse.
Sacks, S., and De Leon, G. Modified therapeutic communities for dual disorders: Evaluation overview. In: Treatment Paradigms: Past, Present, and Future. Proceedings of the Therapeutic Communities of America 1992 National Conference. Washington, DC: Therapeutic Communities of America, 1992.
Sacks S, De Leon G, Balistreri E, Liberty HJ, McKendrick K, Sacks J, Staines G, Yagelka J. (1998a). Modified therapeutic community for homeless mentally ill chemical abusers: Sociodemographic and psychological profiles. Journal of Substance Abuse Treatment.
Sacks, S., De Leon, G., Bernhardt, A.I., and Sacks, J.Y. A modified therapeutic community for homeless mentally ill chemical abusers. In: De Leon, G., ed. Community as Method: Therapeutic Communities for Special Populations and Special Settings. Westport, CT: Praeger Publishers/Greenwood Publishing Group, 1997a. pp. 19–37.
Sacks, S., De Leon, G., Bernhardt, A.I., and Sacks, J.Y. Modified Therapeutic Community for Homeless Mentally Ill Chemical Abusers: Treatment Manual. New York: National Development and Research Institutes, 1998b.
Sacks S, De Leon G, McKendrick K, Brown B, Sacks J. (2003a). TC-oriented supported housing for homeless MICAs. Journal of Psychoactive Drugs.
Sacks, S., and Peters, J. “Modified TC for MICA offenders: Description and interim findings.” Paper presented at the GAINS Center National Conference, San Francisco, October, 2002.
Sacks, S., Peters, J., Wexler, H.K., Roebuck, M.C., and De Leon, G. Modified therapeutic community for MICA offenders: Description and interim findings. Unpublished manuscript b.
Sacks S, Sacks JY, De Leon G. (1999). Treatment for MICAs: Design and implementation of the modified TC. Journal of Psychoactive Drugs.
Sacks S, Sacks J, De Leon G, Bernhardt AI, Staines GL. (1997b). Modified therapeutic community for mentally ill chemical “abusers”: Background; influences; program description; preliminary findings. Substance Use and Misuse.
Sacks, S., Sacks, J.Y., McKendrick, K., Banks, S., and Stommel, J. Modified TC for MICA offenders: Crime outcomes. Behavioral Sciences and The Law (accepted for publication), 2004.
Sacks, S., Sacks, J.Y., and Stommel, J. Modified TC for MICA Inmates in Correctional Settings: A Program Description. Corrections Today, October 2003b.
Sacks, S., Skinner, D., Sacks, J., and Peck, A. Manual for Engaging Homeless MICAs in a Shelter Program. New York: National Development and Research Institutes, 2002.
Safer DJ. (1987). Substance abuse by young adult chronic patients. Hospital and Community Psychiatry.
Samet JH, Rollnick S, Barnes H. (1996). Beyond CAGE: A brief clinical approach after detection of substance abuse. Archives of Internal Medicine.
Saxon AJ, Calsyn DA. (1995). Effects of psychiatric care for dual diagnosis patients treated in a drug dependence clinic. American Journal of Drug and Alcohol Abuse.
Saxon AJ, McGuffin R, Walker RD. (1997). An open trial of transdermal nicotine replacement therapy for smoking cessation among alcohol- and drug-dependent inpatients. Journal of Substance Abuse Treatment.
Scheller-Gilkey G, Woolwine BJ, Cooper I, Gay O, Moynes KA, Miller AH. (2003). Relationship of clinical symptoms and substance use in schizophrenia patients on conventional versus atypical antipsychotics. American Journal of Drug and Alcohol Abuse.
Schorske B, Bedard K. (1989). One State's role in building a continuum of care for severe mental illness and chemical dependency. Community Support Network News.
Schotte DE, Stunkard AJ. (1987). Bulimia vs bulimic behaviors on a college campus. Journal of the American Medical Association.
Schubiner H, Tzelepis A, Milberger S, Lockhart N, Kelley BJ, Schoener EP. (2000). Prevalence of attention-deficit/hyperactivity disorder and conduct disorder among substance abusers. Journal of Clinical Psychiatry.
Schumacher JE, Milby JB, Caldwell E, Raczynski J, Engle M, Michael M, Carr J. (1995). Treatment outcome as a function of treatment attendance with homeless persons abusing cocaine. Journal of Addictive Diseases.
Sciacca K. (1991). Integrated treatment approach for severely mentally ill individuals with substance disorders. New Directions for Mental Health Services.
Seivewright N, Daly C. (1997). Personality disorder and drug use: A review. Drug & Alcohol Review.
Selzer ML. (1971). The Michigan Alcoholism Screening Test: The quest for a new diagnostic instrument. American Journal of Psychiatry.
Sernyak MJ, Leslie DL, Alarcon RD, Losonczy MF, Rosenheck R. (2002). Association of diabetes mellitus with use of atypical neuroleptics in the treatment of schizophrenia. American Journal of Psychiatry.
Shaffer, H.J., Hall, M.N., and Vander Bilt, J. Estimating the Prevalence of Disordered Gambling Behavior in the United States and Canada: A Meta-Analysis. Boston: President and Fellows of Harvard College, 1997. www.hms.harvard.edu/doa/html/meta.pdf[Accessed February 5, 2002].
Shaner A, Roberts LJ, Eckman TA, Tucker DE. (1997). Monetary reinforcement of abstinence from cocaine among mentally ill patients with cocaine dependence. Psychiatric Services.
Shapiro F. (1989). Eye movement desensitization: A new treatment for post-traumatic stress disorder. Journal of Behavior Therapy and Experimental Psychiatry.
Sharpe, L. Cognitive-behavioral treatment of problem gambling. In: Caballo, V.E., ed. International Handbook of Cognitive and Behavioral Treatments for Psychological Disorders. Oxford: Pergamon/Elsevier Science, 1998. pp. 393–416.
Sheehan DV, Lecrubier Y, Sheehan KH, Amorim P, Janavs J, Weiller E, Hergueta T, Baker R, Dunbar GC. (1998). The Mini-International Neuropsychiatric Interview (M.I.N.I): The development and validation of a structured diagnostic psychiatric interview for DSM-IV and ICD-10. Journal of Clinical Psychiatry.
Shern DL, Felton DJ, Hough RL, Lehman AF, Goldfinger S, Valencia E, Dennis D, Straw R, Wood AA. (1997). Housing outcomes for homeless adults with mental illness: Results from the second-round McKinney program. Psychiatric Services.
Shinn M, Knickman JR, Weitzman BC. (1991). Social relations and vulnerability to becoming homeless among poor families. American Psychologist.
Shoptaw S, Jarvik ME. (1996). Contingency management for tobacco smoking in methadone-maintained opiate addicts. Addictive Behaviors.
Sigman GS. (2003). Eating disorders in children and adolescents. Pediatric Clinics of North America.
Silberstein, C.H., Metzger, E.J., and Galanter, M. The Greenhouse: A modified therapeutic community for mentally ill homeless addicts at New York University—Bellevue Medical Center. In: De Leon, G. Community as Method: Therapeutic Communities for Special Populations. Westport, CT: Praeger Publishers, 1997.
Silverman K, Svikis D, Robles E, Stitzer ML, Bigelow GE. (2001). A reinforcement-based therapeutic workplace for the treatment of drug abuse: Six-month abstinence outcomes. Experimental and Clinical Psychopharmacology.
Simpson DD, Joe GW, Broome KM. (2002). A national 5-year follow-up of treatment outcomes for cocaine dependence. Archives of General Psychiatry.
Simpson DD, Joe GW, Brown BS. (1997a). Treatment retention and follow-up outcomes in the Drug Abuse Treatment Outcome Study (DATOS). Psychology of Addictive Behaviors.
Simpson DD, Joe GW, Fletcher BW, Hubbard RL, Anglin MD. (1999). A national evaluation of treatment outcomes for cocaine dependence. Archives of General Psychiatry.
Simpson DD, Joe GW, Rowan-Szal GA. (1997b). Drug abuse treatment retention and process effects on follow-up outcomes. Drug and Alcohol Dependence.
Simpson DD, Knight K, Ray S. (1993). Psychosocial correlates of AIDS-risk drug use and sexual behaviors. AIDS Education and Prevention.
Simpson DD, Sells SB. (1982). Effectiveness of treatment for drug abuse: An overview of the DARP research program. Advances in Alcohol and Substance Abuse.
Simpson TL. (2003). Childhood sexual abuse, PTSD, and the functional roles of alcohol use among women drinkers. Substance Use & Misuse.
Siris, S.G., and Docherty, J.P. Psychosocial management of substance abuse in schizophrenia. In: Herz, M.I., Keith, S.J., and Docherty, J.P., eds. Psychosocial Treatment of Schizophrenia. Handbook of Schizophrenia, Vol. 4. New York: Elsevier, 1990. pp. 339–354.
Skinner HA. (1982). The drug abuse screening test. Journal on Addictive Behaviors.
Skinstad AH, Swain A. (2001). Comorbidity in a clinical sample of substance abusers. American Journal of Drug and Alcohol Abuse.
Sloan KL, Kivlahan D, Saxon AJ. (2000). Detecting bipolar disorder among treatment-seeking substance abusers. American Journal of Drug and Alcohol Abuse.
Slutske WS, Eisen S, True WR, Lyons MJ, Goldberg J, Tsuang M. (2000). Common genetic vulnerability for pathological gambling and alcohol dependence in men. Archives of General Psychiatry.
Sobell LC, Maisto SA, Sobell MB. (1979). Reliability of alcohol abusers' self-reports of drinking behavior. Behavior Research and Therapy.
Solomon, J., Zimberg, S., and Shollar, E., eds. Dual Diagnosis: Evaluation, Treatment, Training, and Program Development. New York: Plenum Medical Book Co., 1993.
Song F, Raftery J, Aveyard P, Hyde C, Barton P, Woolacott N. (2002). Cost-effectiveness of pharmacological interventions for smoking cessation: A literature review and a decision analytic analysis. Medical Decision Making: An International Journal of the Society for Medical Decision Making.
Sonne SC, Brady KT. (1999). Substance abuse and bipolar comorbidity. Psychiatric Clinics of North America.
Soundy TJ, Lucas AR, Suman VJ, Melton LJ. (1995). Bulimia nervosa in Rochester, Minnesota from 1980 to 1990. Psychological Medicine.
Specker S, Westermeyer J. (2000). Course and severity of substance abuse in women with comorbid eating disorder. Substance Abuse.
Stanley AH. (1999). Primary care and addiction treatment: Lessons learned from building bridges across traditions. Journal of Addictive Diseases.
Stapleton JA, Russell MA, Feyerabend C, Wiseman SM, Gustavsson G, Sawe U, Wiseman D. (1995). Dose effects and predictors of outcome in a randomized trial of transdermal nicotine patches in general practice. Addiction.
Stark MJ, Kane BJ. (1985). General and specific psychotherapy role induction with substance-abusing clients. International Journal of the Addictions.
Stark MJ, Campbell BK. (1993a). Cigarette smoking and methadone dose levels. American Journal of Drug and Alcohol Abuse.
Stark MJ, Campbell BK. (1993b). Drug use and cigarette smoking in applicants for drug abuse treatment. Journal of Substance Abuse.
Steadman HJ, Fabisiak S, Dvoskin J, Holohean EJ. (1987). A survey of mental disability among state prison inmates. Hospital and Community Psychiatry.
Steadman H, Mulvey E, Monahan J, Robbins P, Appelbaum P, Grisso T, Roth L, Silver E. (1998). Violence by people discharged from acute psychiatric inpatient facilities and by others in the same neighborhoods. Archives of General Psychiatry.
Steele CM, Josephs RA. (1990). Alcohol myopia: Its prized and dangerous effects. American Psychologist.
Stein, L.I., and Santos, A.B. Assertive Community Treatment of Persons with Severe Mental Illness. New York: W.W. Norton, 1998.
Stein LI, Test MA. (1980). Alternative to mental hospital treatment: I Conceptual model, treatment program, and clinical evaluation. Archives of General Psychiatry.
Steinberg ML, Hall SM, Rustin T. (2003). Psychosocial therapies for tobacco dependence in mental health and other substance use populations. Psychiatric Annals.
Steinberg ML, Williams JM, Ziedonis DM. (2004a). Financial implications of cigarette smoking among individuals with schizophrenia. Tobacco Control.
Steinberg, M.L., Williams, J.M., Steinberg, H.R., Krejci, J.A., and Ziedonis, D.M. Applicability of the Fagerstrom Test for Nicotine Dependence in smokers with schizophrenia. Addictive Behaviors, in press.
Steinberg ML, Ziedonis DM, Krejci JA, Brandon TH. (2004b). Motivational interviewing with personalized feedback: A brief intervention for motivating smokers with schizophrenia to seek treatment for tobacco dependence. Journal of Consulting and Clinical Psychology.
Steiner M. (1998). Perinatal mood disorders: Position paper. Psychopharmacology Bulletin.
Steiner M. (2002). Postnatal depression: A few simple questions. Family Practice.
Steindl SR, Young RM, Creamer M, Crompton D. (2003). Hazardous alcohol use and treatment outcome in male combat veterans with posttraumatic stress disorder. Journal of Traumatic Stress.
Stevens SJ, Erickson JR, Tent JC, Chong J, Gianas P. (1993). Therapeutic community model for treatment of homeless alcohol and drug users in Tucson, Arizona. Alcoholism Treatment Quarterly.
Stinchfield, R., Winters, K.C., Botzet, A., and Jerstand, S. Gambling Treatment Outcome Monitoring System (GAMTOMS): Final Report and User Manual. St. Paul, MN: Mental Health Division, Minnesota Department of Human Services, 2001.
Strakowski SM, Sax KW, McElroy SL, Keck PEJ, Hawkins JM, West SA. (1998). Course of psychiatric and substance abuse syndromes co-occurring with bipolar disorder after a first psychiatric hospitalization. Journal of Clinical Psychiatry.
Strasser TJ, Pike KM, Walsh BT. (1992). The impact of prior substance abuse on treatment outcome for bulimia nervosa. Addictive Behaviors.
Strober, M., Freeman, R., Bower, S., Rigali, J. Binge-eating in anorexia nervosa predicts later onset of substance use disorder. Journal of Youth and Adolescence, in press.
Stuyt EB, Order-Connors B, Ziedonis DM. (2004). Addressing tobacco through program and system change in mental health and addiction settings. Psychiatric Annals.
Substance Abuse and Mental Health Services Administration. Action for Mental Health and Substance-Related Disorders: Improving Services for Individuals at Risk of, or with, Co-occurring Substance-Related and Mental Health Disorders. Conference Report and Recommended National Strategy of the SAMHSA National Advisory Council. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1997.
Substance Abuse and Mental Health Services Administration. Substance Abuse and Mental Health Statistics Sourcebook. DHHS Publication No. (SMA) 98-3170. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998.
Substance Abuse and Mental Health Services Administration. Grants for Evaluation of Outpatient Treatment Models for Persons with Co-Occurring Substance Abuse and Mental Health Disorders. GFA TI 00-002. CFDA #93.230. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000.
Substance Abuse and Mental Health Services Administration. $2.5 Million Awarded in Cooperative Agreements to Improve Substance Abuse Treatment Services. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001. www.samhsa.gov/news/newsreleases/011019nr.grants.htm[Accessed December 14, 2001].
Substance Abuse and Mental Health Services Administration. Report to Congress on the Treatment and Prevention of Co-Occurring Substance Abuse and Mental Disorders. Substance Abuse and Mental Health Services Administration, 2002. www.samhsa.gov/news/cl_congress2002.html[Accessed January 28, 2003].
Sullivan JM, Evans K. (1994). Integrated treatment for the survivor of childhood trauma who is chemically dependent. Journal of Psychoactive Drugs.
Sullivan JT, Sykora K, Schneiderman J, Naranjo CA, Sellers EM. (1989). Assessment of alcohol withdrawal: The revised Clinical Institute Withdrawal Assessment for alcohol scale (CIWA-Ar). British Journal of Addiction.
Sullivan PF. (1995). Mortality in anorexia nervosa. American Journal of Psychiatry.
Sussman S. (2002). Smoking cessation among persons in recovery. Substance Use and Misuse.
Swanson AJ, Pantalon MV, Cohen KR. (1999). Motivational interviewing and treatment adherence among psychiatric and dually diagnosed patients. Journal of Nervous and Mental Disease.
Taber JI, McCormick RA, Russo AM, Adkins BJ, Ramirez LF. (1987). Follow-up of pathological gamblers after treatment. American Journal of Psychiatry.
Taylor AV, Peveler RC, Hibbert GA, Fairburn CG. (1993). Eating disorders among women receiving treatment for an alcohol problem. International Journal of Eating Disorders.
Taylor RC, Harris NA, Singleton EG, Moolchan ET, Heishman SJ. (2000). Tobacco craving: Intensity-related effects of imagery scripts in drug abusers. Experimental and Clinical Psychopharmacology.
Teague GB, Bond GR, Drake RE. (1998). Program fidelity in assertive community treatment: Development and use of a measure. American Journal of Orthopsychiatry.
Teague GB, Drake RE, Ackerson TH. (1995). Evaluating use of continuous treatment teams for persons with mental illness and substance abuse. Psychiatric Services.
Teplin LA. (1990). The prevalence of severe mental disorder among male urban jail detainees: Comparison with the Epidemiologic Catchment Area Program. American Journal of Public Health.
Test, M.A. Training in community living. In: Liberman, R.P., ed. Handbook of Psychiatric Rehabilitation. New York: Macmillan Publishing, 1992. pp. 153–170.
The Change Book: A Blueprint for Technology Transfer. Kansas City, MO: ATTC National Office, 2000. www.nattc.org/pdf/changebook.pdf[Accessed August 27, 2002].
Therapeutic Communities of America. Therapeutic Communities in Correctional Settings: The Prison Based TC Standards Development Project. Final Report of Phase II. Washington, DC: Office of National Drug Control Policy, 1999. www.whitehousedrugpolicy.gov/national_assembly/publications/therap_comm/therap_comm.pdf[Accessed January 28, 2002].
Thomas SE, Randall CL, Carrigan MH. (2003). Drinking to cope in socially anxious individuals: A controlled study. Alcoholism: Clinical and Experimental Research.
Tomasson K, Vaglum P. (1998). The role of psychiatric comorbidity in the prediction of readmission for detoxification. Comprehensive Psychiatry.
Treatment of Persons With Co-occurring Disorders: Program Examples. Unpublished report accompanying the Co-Occurring Institute at the State Systems Development Program V Conference, Orlando, FL, 2000.
Triffleman, E. An overview of trauma exposure, posttraumatic stress disorder, and addictions. In: Kranzler, H.R., and Rounsaville, B.J., eds. Dual Diagnosis and Treatment: Substance Abuse and Comorbid Medical and Psychiatric Disorders. 2d ed. New York: Marcel Dekker, 1998. pp. 263–316.
Triffleman E. (2000). Gender differences in a controlled pilot study of psychosocial treatment in substance dependent patients with post-traumatic stress disorder: Design considerations and outcomes. Alcoholism Treatment Quarterly.
Triffleman E, Carroll K, Kellogg S. (1999). Substance dependence posttraumatic stress disorder therapy: An integrated cognitive-behavioral approach. Journal of Substance Abuse Treatment.
Trotter, C. Double Bind: A Guide to Recovery and Relapse Prevention for the Chemically Dependent Sexual Abuse Survivor. Independence, MO: Herald House/Independence Press, 1992.
Trotzky AS. (2002). The treatment of eating disorders as addiction among adolescent females. International Journal of Adolescent Medicine and Health.
Tsemberis S, Asmussen S. (1999). From streets to homes: The Pathways to Housing Consumer Preference Supported Housing Model. Alcoholism Treatment Quarterly.
Tsemberis S, Eisenberg RF. (2000). Pathways to Housing: Supported housing for street-dwelling homeless individuals with psychiatric disabilities. Psychiatric Services.
Tsemberis S, Moran LL, Shinn M, Asmussen SM, Shern DL. (2003). Consumer preference programs for homeless individuals with psychiatric disabilities: A drop-in center and a supported housing program. American Journal of Community Psychology.
Tucker, J.A., Donovan, D.M., and Marlatt, G.A., eds. Changing Addictive Behavior: Bridging Clinical and Public Health Strategies. New York: Guilford Press, 1999.
Tyrer, P., Casey, P., and Ferguson, B. Personality disorder and mental illness. In: Tyrer, P., ed. Personality Disorders: Diagnosis, Management and Course. Kent, England: Wright/Butterworth Scientific, 1988. pp. 93–104.
U.S. Census Bureau. Table 1: States Ranked by Population. 2000. Census 2000: PHC-T-2. Ranking Tables for States. 1990 and 2000. Washington, DC: U.S. Census Bureau, 2001. www.census.gov/population/cen2000/phc-t2/tab01.pdf[Accessed March 12, 2002].
U.S. Public Health Service, Office of the Surgeon General. The Health Consequences of Smoking: A Report of the Surgeon General, May 2004. Atlanta, GA: Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office of Smoking and Health, 2004. www.surgeongeneral.gov/library/smokingconsequences/[Accessed June 17, 2004].
U.S. Public Health Service. The Surgeon General's Call to Action to Prevent Suicide. Washington, DC, 1999. www.surgeongeneral.gov/library/calltoaction/calltoaction.htm[Accessed March 29, 2002].
Vaillant, G.E. The Natural History of Alcoholism Revisited. Cambridge: Harvard University Press, 1995.
Vaiva G, Ducrocq F, Jezequel K, Averland B, Lestavel P, Brunet A, Marmar CR. (2003). Immediate treatment with propranolol decreases posttraumatic stress disorder two months after trauma. Biological Psychiatry.
Valle SK. (1981). Interpersonal functioning of alcoholism counselors and treatment outcome. Journal of Studies on Alcohol.
Varan LR, Gillieson MS, Skene DS, Sarwer-Foner GJ. (1985). ECT in an acutely psychotic pregnant woman with actively aggressive (homicidal) impulses. Canadian Journal of Psychiatry.
Verheul R, Kranzler HR, Poling J, Tennen H, Ball S, Rounsaville BJ. (2000). Co-occurrence of Axis I and Axis II disorders in substance abusers. Acta Psychiatrica Scandinavica.
von der Stein B, Podoll K. (1999). Self-cutting syndrome in the history of patients with alcoholism. Neurology, Psychiatry, and Brain Research.
Wadsworth, N.S., and Fall Creek, S.J. Culturally competent care teams. In: Wykle, M.L., and Ford, A.B., eds. Serving Minority Elders in the 21st Century. New York: Springer Publishing, 1999. pp. 248–266.
Waid, L.R., Johnson, D.E., and Anton, R.F. Attention-deficit hyperactivity disorder and substance abuse. In: Kranzler, H.R., and Rounsaville, B.J., eds. Dual Diagnosis and Treatment: Substance Abuse and Comorbid Medical and Psychiatric Disorders. 2d ed. New York: Marcel Dekker, 1998. pp. 393–426.
Walfish S, Stenmark DE, Sarco D, Shealy JS, Krone AM. (1992). Incidence of bulimia in substance misusing women in residential treatment. International Journal of the Addictions.
Walitzer, K.S., and Connors, G.J. Gender and treatment of alcohol-related problems. In: Wilsnack, R.W., and Wilsnack, S.C., eds. Gender and Alcohol: Individual and Social Perspectives. New Brunswick, NJ: Rutgers Centers of Alcohol Studies, 1997. pp. 445–461.
Walker RD, Howard MO, Lambert MD, Suchinsky R. (1994). Psychiatric and medical comorbidities of veterans with substance use disorders. Hospital and Community Psychiatry.
Ward MF, Wender PH, Reimherr FW. (1993). The Wender Utah Rating Scale: An aid in the retrospective diagnosis of childhood attention deficit hyperactivity disorder. American Journal of Psychiatry.
Watkins KE, Burnam A, Kung F-Y, Paddock S. (2001). A national survey of care for persons with co-occurring mental and substance use disorders. Psychiatric Services.
Weaver, M.F. Perinatal addiction. In: Graham, A.W., Schultz, T.K., Mayo-Smith, M.F., Ries, R.K, and Wilford, B.B., eds. Principles of Addiction Medicine, 3d ed. Chevy Chase, MD: American Society of Addiction Medicine, 2003. pp. 1231–1246.
Webster J, Linnane JW, Dibley LM, Pritchard M. (2000). Improving antenatal recognition of women at risk for postnatal depression. Australian and New Zealand Journal of Obstetrics and Gynaecology.
Weiner S. (1998). The addiction of overeating: Self-help groups as treatment models. Journal of Clinical Psychology.
Weisner C, Mertens J, Parthasarathy S, Moore C, Lu Y. (2001). Integrating primary medical care with addiction treatment. JAMA.
Weiss, D.S., and Billings, J.H. Behavioral medicine techniques. In: Goldman, H.H., ed. Review of General Psychiatry, 2d ed. Norwalk, CT: Appleton & Lange, 1989. pp. 574–579.
Weiss RD, Martinez-Raga J, Griffin ML, Greenfield SF, Hufford C. (1997). Gender differences in cocaine dependent patients: A 6 month follow-up study. Drug and Alcohol Dependence.
Weiss RD, Najavits LM, Greenfield SF. (1999). A relapse prevention group for patients with bipolar and substance use disorders. Journal of Substance Abuse Treatment.
Weiss, R.D., Najavits, L.M., Greenfield, S.F., Soto, J., and Wyner, D. Relapse prevention group therapy for patients with coexisting substance use disorder and bipolar disorder. In: Problems of Drug Dependence 1997. Proceedings of the 59th Annual Scientific Meeting. NIDA Research Monograph 178. NIH Publication No. 98-4305. Rockville, MD: National Institute on Drug Abuse, 1998. p. 253.
Wells EA, Peterson PL, Hawkins JD. (1994). Outpatient treatment for cocaine abuse: A controlled comparison of relapse prevention and twelve-step approaches. American Journal of Drug and Alcohol Abuse.
Wells JE, Bushnell JA, Hornblow AR, Joyce PR, Oakley-Browne MA. (1989a). Christchurch Psychiatric Epidemiology Study, Part I: Methodology and lifetime prevalence for specific psychiatric disorders. Australian & New Zealand Journal of Psychiatry.
Wells KB, Golding JM, Burnam MA. (1989b). Chronic medical conditions in a sample of the general population with anxiety, affective, and substance use disorders. American Journal of Psychiatry.
Westefeld JS, Range LM, Rogers JR, Maples MR, Bromley JL, Alcorn J. (2000). Suicide: An overview. Counseling Psychologist.
Westermeyer JJ, Schneekloth TD. (1999). Course of substance abuse in patients with and without schizophrenia. American Journal on Addictions.
Westermeyer J, Specker S. (1999). Social resources and social function in comorbid eating and substance disorder: A matched-pairs study. American Journal on Addictions.
Wewers ME, Stillman FA, Hartman AM, Shopland DR. (2003). Distribution of daily smokers by stage of change: Current Population Survey results. Preventive Medicine.
Wexler H, De Leon G, Thomas G, Kressel D, Peters J. (1999). Amity Prison TC evaluation: Reincarceration outcomes. Criminal Justice and Behavior.
White, W.L. Pathways: From the Culture of Addiction to the Culture of Recovery. A Travel Guide for Addiction Professionals. 2d ed. Center City, MN: Hazelden, 1996.
Whitehouse AM, Cooper PJ, Vize CV, Hill C, Vogel L. (1992). Prevalence of eating disorders in three Cambridge general practices: Hidden and conspicuous morbidity. British Journal of General Practice.
Willenbring ML, Olson DH. (1999). A randomized trial of integrated outpatient treatment for medically ill alcoholic men. Archives of Internal Medicine.
Williams, V.F., Banks, S.M., Robbins, P.C., Oakley, D., and Dean, J. Final Report on the Cross-Site Evaluation of the Collaborative Program to Prevent Homelessness. Delmar, NY: Policy Research Associates, 2001.
Williams JM, Hughes JR. (2003). Pharmacotherapy treatments for tobacco dependence among smokers with mental illness or addiction. Psychiatric Annals.
Williams JM, Ziedonis DM. (2004). Addressing tobacco among individuals with a mental illness or an addiction. Addictive Behaviors.
Williams JM, Ziedonis DM, Foulds J. (2004). A case series of nicotine nasal spray in the treatment of tobacco dependence among patients with schizophrenia: A case series. Psychiatric Services.
Wilson JR. (1992). Bulimia nervosa: Occurrence with psychoactive substance use disorders. Addictive Behaviors.
Winarski, J.T., and Dubus, P. An Analysis of 16 Federally-Funded Programs for Homeless Individuals with Co-Occurring Mental Health and Substance Use Disorders. Newton Centre, MA: The Better Homes Fund, 1994.
Windle M. (1999). Psychopathy and antisocial personality disorder among alcoholic inpatients. Journal of Studies on Alcohol.
Wingerson D, Ries RK. (1999). Assertive Community Treatment for patients with chronic and severe mental illness who abuse drugs. Journal of Psychoactive Drugs.
Winters, K.C. Clinicians Guide to Self-Evaluation Workbook for Alcohol and Drug Abuse: Screening for Alcohol and Drug Abuse (SADA). Center City, MN: Hazelden, 1995.
Wolff N, Helminiak TW, Morse GA, Calsyn RJ, Klinkenberg WD, Trusty ML. (1997). Cost-effectiveness evaluation of three approaches to case management for homeless mentally ill clients. American Journal of Psychiatry.
Women for Sobriety. “New Life” Acceptance Program. Quakertown, PA: Women for Sobriety, 1993. www.womenforsobriety.org/wfs_program.html[Accessed July 30, 2002].
Woody, G.E., and Blaine, J. Depression in narcotic addicts: Quite possibly more than a chance association. In: Dupont, R., Goldstein, A., and O'Donnell, J., eds. Handbook of Drug Abuse. Rockville, MD: National Institute on Drug Abuse, 1979. pp. 277–285.
Woody GE, Luborsky L, McLellan AT, O'Brien CP, Beck AT, Blaine J, Herman I, Hole A. (1983). Psychotherapy for opiate addicts: Does it help?. Archives of General Psychiatry.
Woody GE, McLellan AT, Luborski L, O'Brien CP, Blaine J, Fox S, Herman I, Beck AT. (1984). Severity of psychiatric symptoms as a predictor of benefits from psychotherapy: The Veterans Administration-Penn Study. American Journal of Psychiatry.
Woody, G.E., McLellan, A.T., O'Brien, C.P., and Luborsky, L. Addressing psychiatric co-morbidity. In: Pickens, R.W., Leukefeld, C.G., and Schuster, C.R., eds. Improving Drug Abuse Treatment. NIDA Research Monograph 106. Rockville, MD: National Institute on Drug Abuse, 1991. pp. 152–166.
Woolacott, N.F., Jones, L., Forbes, C.A., Mather, L.C., Sowden, A.J., Song, F.J., Raftery, J.P., Aveyard, P.N., Hyde, C.J., and Barton, P.M. The clinical effectiveness and cost-effectiveness of bupropion and nicotine replacement therapy for smoking cessation: A systematic review and economic evaluation. Health Technology Assessment 6(16):12–45, 2002. www.ncchta.org/fullmono/mon616.pdf. [Accessed November 16, 2004].
World Health Organization. International Statistical Classification of Diseases and Related Health Problems. 10th revision ed. Geneva: World Health Organization, 1992.
Wray I, Dickerson MG. (1981). Cessation of high frequency gambling and “withdrawal” symptoms. British Journal of Addiction.
Yehuda, R., ed. Treating Trauma Survivors with PTSD. Washington, DC: American Psychiatric Publishing, Inc., 2002.
Yoshikawa T, Sugiyama Y, Sawada Y, ga T, Hanano M, Kawasaki S, Yanagida M. (1984). Effect of late pregnancy on salicylate, diazepam, warfarin, and propranolol binding: Use of fluorescent probes. Clinical Pharmacology and Therapeutics.
Young, J.E. Cognitive Therapy for Personality Disorders: A Schema-Focused Approach. Rev. ed. Sarasota, FL: Professional Resource Press, 1994.
Zhu S, Melcer T, Sun J, Rosbrook B, Pierce JP. (2000). Smoking cessation with and without assistance: A population-based analysis. American Journal of Preventive Medicine.
Zickler, P. Nicotine craving and heavy smoking may contribute to increased use of cocaine and heroin. NIDA NOTES 15(5): 2000.
Ziedonis, D.M., and D'Avanzo, K. Schizophrenia and substance abuse. In: Kranzler, H.R., and Rounsaville, B.J., eds. Dual Diagnosis and Treatment: Substance Abuse and Comorbid Medical and Psychiatric Disorders. New York: Marcel Dekker, Inc., 1998.
Ziedonis, D., and Fiester, S. Substance abuse: Nicotine dependence. In: Tasman, A., ed. Psychiatry. 2d ed. London: John Wiley and Sons, 2003.
Ziedonis DM, George TP. (1997). Schizophrenia and nicotine use: Report of a pilot smoking cessation program and review of neurobiological and clinical issues. Schizophrenia Bulletin.
Ziedonis DM, Kosten TR, Glazer WM, Frances RJ. (1994). Nicotine dependence and schizophrenia. Hospital and Community Psychiatry.
Ziedonis DM, Stern R. (2001). Dual recovery therapy for schizophrenia and substance abuse. Psychiatric Annals.
Ziedonis D, Williams J. (2003a). Addressing tobacco use in mental health and addiction settings. Psychiatric Annals.
Ziedonis DM, Williams J. (2003b). Management of smoking in people with psychiatric disorders. Current Opinion in Psychiatry.
Ziedonis D, Williams JM, Smelson D. (2003). Serious mental illness and tobacco addiction: A model program to address this common but neglected issue. American Journal of Medical Sciences.
Ziedonis, D.M., and Wyatt, S.A. Psychotic disorders. In: Graham, A.W., Schultz, T.K., and Wilford, B.B., eds. Principles of Addiction Medicine. 2d ed. Chevy Chase, MD: American Society of Addiction Medicine, 1998. pp. 1007–1027.
Zilm DH, Sellers EM. (1978). The quantitative assessment of physical dependence on opiates. Drug and Alcohol Dependence.
Zimberg, S. Introduction and general concepts of dual diagnosis. In: Solomon, J., Zimberg, S., and Shollar, E., eds. Dual Diagnosis: Evaluation, Treatment, Training, and Program Development. New York: Plenum Medical Book Co., 1993. pp. 3–21.
Zukin, S.R., and Zukin, R.S. Phencyclidine. In: Lowinson, J.H., Ruiz, P., Millman, R.B., and Langrod, J.G., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins, 1992. pp. 290–302.