# Consensus Panel

## Chair

- Stanley Sacks, Ph.D.
- Director
- Center for the Integration of Research and Practice
- National Development and Research Institutes, Inc.
- New York, New York

## Co-Chair

- Richard K. Ries, M.D.
- Director/Professor
- Outpatient Mental Health Services
- Dual Disorder Programs
- Harborview Medical Center
- Seattle, Washington

## Workgroup Leaders

- Donna Nagy McNelis, Ph.D.
- Director, Behavioral Healthcare Education
- Associate Professor, Psychiatry
- Drexel University
- School of Medicine
- Philadelphia, Pennsylvania

- David Mee-Lee, M.D., FASAM
- Davis, California

- James L. Sorenson, Ph.D.
- Department of Psychiatry
- San Francisco General Hospital
- San Francisco, California

- Douglas Ziedonis, M.D.
- Director, Addiction Services
- University Behavioral Healthcare System
- Piscataway, New Jersey

- Joan E. Zweben, Ph.D.
- Executive Director
- The 14th Street Clinic and Medical Group
- East Bay Community Recovery Project
- University of California
- Berkeley, California

## Panelists

- Betty Blackmon, M.S.W., J.D.
- Parker-Blackmon and Associates
- Kansas City, Missouri

- Steve Cantu, LCDC, CADAC, RAS
- Clinical Program Coordinator
- South Texas Rural Health Services, Inc.
- Cotulla, Texas

- Catherine S. Chichester, M.S.N., R.N., CS
- Executive Director
- Co-Occurring Collaborative of Southern Maine
- Portland, Maine

- Colleen Clark, Ph.D.
- Research Associate
- Department of Community Mental Health
- University of South Florida
- Tampa, Florida

- Christie A. Cline, M.D., M.B.A.
- Medical Director
- Behavioral Health Sciences Division
- New Mexico Department of Health
- Santa Fe, New Mexico

- Raymond Daw, M.A.
- Executive Director
- Na'nizhoozhi Center, Inc.
- Gallup, New Mexico

- Sharon C. Ekleberry, L.C.S.W., L.S.A.T.P, B.C.D.
- Division Director
- Adult Outpatient Services
- Fairfax County Mental Health Services
- Fairfax/Falls Church Community Services Board
- Centreville, Virginia

- Byron N. Fujita, Ph.D.
- Senior Psychologist
- Clackamas County Mental Health Center
- Oregon City, Oregon

- Lewis E. Gallant, Ph.D.
- Executive Director
- National Association of State Alcohol and Drug Abuse Directors, Inc.
- Washington, DC

- Michael Harle, M.H.S.
- President/Executive Director
- Gaudenzia, Inc.
- Norristown, Pennsylvania

- Michael W. Kirby, Jr., Ph.D.
- Chief Executive Officer
- Arapahoe House, Inc.
- Thornton, Colorado

- Kenneth Minkoff, M.D.
- Medical Director
- Choate Health Management
- Woburn, Massachusetts

- Lisa M. Najavits, Ph.D.
- Associate Professor of Psychology
- Harvard Medical School/McLean Hospital
- Belmont, Massachusetts

- Tomas A. Soto, Ph.D.
- Director
- Behavioral Sciences
- The CORE Center
- Chicago, Illinois

The Chair and Co-Chair would like to thank Kenneth Minkoff, M.D., for his valuable contributions to chapter 4 of this TIP.

Special thanks go to Douglas Ziedonis, M.D., for providing content on nicotine; Donna Nagy McNelis, Ph.D., for providing content for the workforce development section; Tim Hamilton, for providing content for the section on dual recovery self-help groups in chapter 7; Theresa Moyers, Ph.D., for her critical review of the motivational interviewing section; George A. Parks, Ph.D., for his input into the relapse prevention section; Cynthia M. Bulik, Ph.D., for writing the section on eating disorders; Lisa M. Najavits, Ph.D., for her contributions to the PTSD section; Loreen Rugle, Ph.D., for writing the section on gambling disorders; Barry S. Brown, Ph.D., for providing consultation to the Chair; and Jo Scraba for her editorial assistance to the Chair.