# Acknowledgments

Numerous people contributed to the development of this TIP (see pp. xi, xiii, and appendices L, M, and N). This publication was produced by The CDM Group, Inc. under the Knowledge Application Program (KAP) contract, number 270-99-7072 with the Substance Abuse and Mental Health Services Administration (SAMHSA), U.S. Department of Health and Human Services (DHHS). Karl D. White, Ed.D., and Andrea Kopstein, Ph.D., M.P.H., served as the Center for Substance Abuse Treatment (CSAT) Government Project Officers. Christina Currier served as the CSAT TIPs Task Leader. Rose M. Urban, M.S.W., J.D., LCSW, CCAC, CSAC, served as the CDM KAP Executive Deputy Project Director. Elizabeth Marsh served as the CDM KAP Deputy Project Director. Shel Weinberg, Ph.D., served as the CDM KAP Senior Research/Applied Psychologist. Other KAP personnel included Raquel Witkin, M.S., Deputy Project Manager; Susan Kimner, Managing Editor; Deborah Steinbach, Senior Editor/Writer; and Erica Flick, Editorial Assistant. In addition, Sandra Clunies, M.S., I.C.A.D.C., served as Content Advisor. Special thanks go to Susan Hills, Ph.D., for serving as Co-Editor on this TIP, and Doug Ziedonis, M.D., for his contribution to chapter 8. Jonathan Max Gilbert, M.A., Margaret K. Hamer, M.P.A., Randi Henderson, B.A., Susan Hills, Ph.D., and David Shapiro, M.S., M.Ed., were writers. Appendix K was prepared by Margaret Brooks, J.D., and SAMHSA staff in consultation with the Office of the General Counsel, the U.S. Department of Health and Human Services, Washington, D.C.