# Foreword

Our Nation has made great strides in recent years in achieving recovery for persons with substance use disorders. We know much more about how to deliver recovery‐oriented substance abuse treatment, improve service quality, achieve desired improvements in quality‐of‐life outcomes, and implement needed care systems in each community in the United States. Our vision is of a life in the community for everyone.

The Treatment Improvement Protocol (TIP) series promotes resilience and facilitates recovery from substance use disorders. The TIPs add to our knowledge base and provide best practice guidance to clinicians, program administrators, and payors. They are the result of careful consideration of all relevant clinical and health services research findings, demonstration experience, and implementation requirements. For each TIP topic, an expert panel of non‐Federal clinical researchers, clinicians, program administrators, and patient advocates debates and discusses best practices until its members reach a consensus.

The talent, dedication, and hard work that TIPs panelists and reviewers bring to this highly participatory process have bridged the gap between the promise of research and the needs of practicing clinicians and administrators. We are grateful to all who have joined with us to contribute to advances in the substance use disorder treatment field.

We hope you will find many uses for the information contained in this volume and that you will join in our goal of helping all Americans with substance use disorders realize healthy, contributing lives in their communities nationwide.

Charles G. Curie, M.A., A.C.S.W.

Administrator

Substance Abuse and Mental Health Services Administration

H. Westley Clark, M.D., J.D., M.P.H., CAS, FASAM

Director, Center for Substance Abuse Treatment Substance Abuse and Mental Health Services Administration