# Buprenorphine Expert Panel

## Chair

- Eric C. Strain, M.D.
- Professor
- Johns Hopkins University School of Medicine
- Baltimore, Maryland

- Leslie Amass, Ph.D.
- Principal Investigator
- Friends Research Institute, Inc.
- Los Angeles, California

- David Fiellin, M.D.
- Associate Professor of Medicine
- Yale University School of Medicine
- Primary Care Center
- Yale‐New Haven Hospital
- New Haven, Connecticut

- R. E. Johnson, Pharm.D.
- Professor
- Department of Psychiatry and Behavioral Sciences
- Behavioral Pharmacology Research Unit
- Johns Hopkins University School of Medicine
- Baltimore, Maryland

- Thomas R. Kosten, M.D.
- Professor of Psychiatry
- Yale University School of Medicine
- Deputy Chief of Psychiatry Research
- VA Connecticut Healthcare System
- West Haven, Connecticut

- James J. Manlandro, D.O.
- Medical Director
- Family Addiction Treatment Services
- Rio Grande, New Jersey

- Elinore F. McCance‐Katz, M.D., Ph.D.
- Professor of Psychiatry and Chair
- Addiction Psychiatry
- Medical College of Virginia
- Virginia Commonwealth University
- Richmond, Virginia

- Joe Merrill, M.D., M.P.H.
- Research Scientist
- Division of General Medicine
- Harborview Medical Center
- Seattle, Washington

- Geoff Mumford, Ph.D.
- American Psychological Association
- Washington, District of Columbia

- Richard T. Suchinsky, M.D.
- Associate Director for Addictive Disorders and Psychiatric Rehabilitation
- U.S. Department of Veterans Affairs
- Veterans Health Administration
- Washington, District of Columbia