# Panelists

- Tony Aguilar, L.M.F.T.
- Legislative Consultant
- California Department of Social Services
- Sacramento, California

- Daniel Alford, M.D., M.P.H.
- Association for Medical Education and Research in Substance Abuse (AMERSA)
- Assistant Professor of Medicine
- Boston University School of Medicine
- Clinical Addiction Research and Education Unit
- Boston, Massachusetts

- Catherine T. Baca, M.D.
- Clinical Supervisor
- Center on Alcoholism, Substance Abuse, and Addictions
- Albuquerque, New Mexico

- Thomas J. Croce, Jr., R.Ph. (replacing Jann B. Skelton)
- Senior Manager
- Strategic Alliances
- American Pharmaceutical Association
- Philadelphia, Pennsylvania

- George De Leon, Ph.D.
- Director
- Center for Therapeutic Community Research of The National Development and Research Institutes
- New York, New York

- Elizabeth F. Howell, M.D.
- Senior Medical Editor
- Atlanta, Georgia

- Martin Iguchi, Ph.D.
- Senior Behavioral Scientist
- Director
- Drug Policy Research Center
- Rand Corporation
- Santa Monica, California

- Herbert D. Kleber, M.D.
- Professor of Psychiatry
- Director
- The Division on Substance Abuse
- Columbia University
- New York, New York

- Ervin Lewis, M.D.
- Area Chief Medical Officer
- Albuquerque Area Indian Health Service
- Albuquerque, New Mexico

- James J. Manlandro, D.O.
- Medical Director
- Family Addiction Treatment Services
- Rio Grande, New Jersey

- Andrew J. Saxon, M.D.
- Professor
- Department of Psychiatry and Behavioral Sciences
- University of Washington
- Center of Excellence in Substance Abuse Treatment and Education
- VA Puget Sound Health Care System
- Seattle, Washington

- Charles R. Schuster, Ph.D.
- Professor
- Department of Psychiatry and Behavioral Neuroscience
- Wayne State University School of Medicine
- Detroit, Michigan

- Audrey Sellers, M.D.
- Medical Director
- Bay Area Addiction Research and Treatment, Inc.
- San Francisco, California

- Jann B. Skelton, R.Ph., M.B.A.
- Vice President
- U.S. Wellness, Inc.
- Gaithersburg, Maryland

- David E. Smith, M.D.
- President and Founder
- Haight Ashbury Free Clinic
- San Francisco, California

- Eric C. Strain, M.D.
- Professor
- Johns Hopkins University School of Medicine
- Baltimore, Maryland

- Joycelyn Woods, M.A.
- President
- National Alliance of Methadone Advocates
- New York, New York