# Consensus Panel

## Chair

- Laura McNicholas, M.D., Ph.D.
- Clinical Assistant Professor
- Department of Psychiatry
- University of Pennsylvania Treatment Research Center
- Philadelphia, Pennsylvania