# Acknowledgments

Numerous people contributed to the development of this TIP (see pp. ix, xi, and appendix J). This publication was produced by the American Institutes for Research^®^ (AIR) under the Center for Substance Abuse Treatment (CSAT) contract, task order number 277‐00‐6401 under the Substance Abuse and Mental Health Services Administration (SAMHSA) contract, Number 277‐99‐6400, U.S. Department of Health and Human Services (DHHS). CAPT Susanne Caviness, Ph.D., SR SURG Angel A. González, M.D., and Raymond Hylton, Jr., R.N., M.S.N., served as the CSAT Government Project Officers. Anton C. Bizzell, M.D., and Alan Trachtenberg, M.D., M.P.H., served as the CSAT Medical Editors. Christina Currier served as the CSAT TIPs Task Leader. Elizabeth F. Howell, M.D., served as the Senior Medical Editor. Wayne Brandes, D.O., M.P.H., served as the AIR Medical Editor and Project Director. Janet Carrese served as the AIR Deputy Project Director. Other AIR personnel included Susan Bratten, Senior Editor; Susan Keller, M.P.H., M.S., B.S.N., Quality Assurance Editor; and Patricia Louthian, Document Production Specialist. In addition, Center for Health Policy Studies (CHPS) Consulting staff Roy Walker, M.B.A., Kimberly Stern, M.H.A., Elly Gilbert, M.S., R.N., C.H.E.S., and Ji Kim served as the original support team for the consensus and field review panels. Writers were Margaret Boone, Ph.D.; Nancy J. Brown; Mary A. Moon; Deborah J. Schuman; Josephine Thomas, M.F.A.; and Denise L. Wright, Ph.D.