# 6 Policies and Procedures

## Overview

This chapter discusses policies and procedures relating to the Drug Addiction Treatment Act of 2000 (DATA 2000), to preparations for providing opioid addiction treatment in practices that are new to this form of care, to State and Federal laws and regulations that protect the privacy and confidentiality of addiction treatment information, and to the use of buprenorphine in federally regulated Opioid Treatment Programs (OTPs). Physicians should become thoroughly familiar with these issues before engaging in the practice of opioid addiction treatment (Brooks 1997). In addition, readers are referred to appendix F, which contains additional information about many of these topics.

## The DATA 2000 Waiver

DATA 2000 enables qualifying physicians to receive a waiver from the special registration requirements in the Narcotic Addict Treatment Act (NATA) of 1974 (and its enabling regulations, including Title 42, Part 8 of the Code of Federal Regulations, that govern OTPs) for the provision of opioid addiction treatment. This waiver allows qualifying physicians (see “Physician Waiver Qualifications”) to prescribe or dispense Schedule III, IV, and V “narcotic” medications for the treatment of opioid addiction in the office and other clinical settings if (and only if) those medications have been approved by the Food and Drug Administration (FDA) for use in addiction treatment. As of this writing, Subutex® (buprenorphine) and Suboxone® (buprenorphine/naloxone) sublingual tablets are the only Schedule III, IV, or V pharmaceuticals to have received such FDA approval. NATA makes it illegal for narcotics to be used “off label” to treat opioid addiction. This prohibition extends even to other forms of buprenorphine (e.g., Buprenex®) that have not been specifically approved for the treatment of opioid addiction.

### Notification of Intent

To receive a DATA 2000 waiver to practice opioid addiction treatment with approved Schedule III, IV, and V opioid medications, a physician must notify the Substance Abuse and Mental Health Services Administration (SAMHSA) of his or her intent to begin dispensing or prescribing this treatment. This Notification of Intent must be submitted to SAMHSA before the initial dispensing or prescribing of opioid treatment. Notification of Intent forms can be obtained on the SAMHSA Buprenorphine Web site athttp://www.buprenorphine.samhsa.gov. Forms can be submitted to SAMHSA online or printed out and then submitted via ground mail or fax.

The Notification of Intent must contain information on the physician’s qualifying credentials (as defined below) and additional certifications, including that the physician has the capacity to refer addiction patients for appropriate counseling and other nonpharmacological therapies, and that the physician will not have more than 30 patients on such addiction treatment at any one time. (Note that the 30‐patient limit applies both to physicians in solo practice and to entire group practices, and the limit is not affected by the number of locations of practice of the physicians or groups.)

Physicians who meet the qualifications defined in DATA 2000 are issued a waiver by SAMHSA and a special identification number by the Drug Enforcement Administration (DEA). DEA has issued regulations that require physicians to include this identification number on all records when dispensing and on all prescriptions when prescribing approved opioid medications (currently only Subutex® and Suboxone®) for opioid addiction.

### Immediate‐Type Notifications

Under DATA 2000, a physician may initiate opioid addiction treatment for “an individual patient” after submitting a Notification of Intent to SAMHSA but before receipt of a waiver and identification number. To provide this “immediate‐type” treatment, a physician must not only submit the usual Notification of Intent to SAMHSA but also must include notification of intent to begin immediately treating an individual patient. SAMHSA’s Notification of Intent form includes a checkbox for indicating this immediate‐type intent.

### Physician Waiver Qualifications

To qualify for a waiver under DATA 2000, a licensed physician (M.D. or D.O.) must meet any one or more of the following criteria:

- The physician holds a subspecialty board certification in addiction psychiatry from the American Board of Medical Specialties.
- The physician holds an addiction certification from the American Society of Addiction Medicine (ASAM).
- The physician holds a subspecialty board certification in addiction medicine from the American Osteopathic Association (AOA).
- The physician has, with respect to the treatment and management of patients who are opioid addicted, completed not less than 8 hours of training (through classroom situations, seminars at professional society meetings, electronic communications, or otherwise) that is provided by ASAM, the American Academy of Addiction Psychiatry, the American Medical Association, AOA, the American Psychiatric Association, or any other organization that the Secretary of the U.S. Department of Health and Human Services (DHHS) determines is appropriate for purposes of this subclause.
- The physician has participated as an investigator in one or more clinical trials leading to the approval of a narcotic drug in Schedule III, IV, or V for maintenance or detoxification treatment, as demonstrated by a statement submitted to the DHHS Secretary by the sponsor of such approved drug.
- The physician has such other training or experience as the State medical licensing board (of the State in which the physician will provide maintenance or detoxification treatment) considers to demonstrate the ability of the physician to treat and manage patients who are opioid addicted.
- The physician has such other training or experience as the DHHS Secretary considers as demonstrating the ability of the physician to treat and manage opioid‐dependent patients. Any criteria of the DHHS Secretary under this subclause shall be established by regulation.

### For More Information

Proper training on the use of buprenorphine will be key to the successful introduction of this new treatment paradigm, regardless of the clinical setting of buprenorphine treatment. Thus, SAMHSA and the consensus panel strongly encourage all physicians who plan to practice opioid addiction treatment with buprenorphine to participate in a DATA 2000‐qualifying 8‐hour training program on buprenorphine. SAMHSA maintains a list of upcoming DATA 2000‐qualifying buprenorphine training sessions on the SAMHSA Buprenorphine Web site at http://www.buprenorphine.samhsa.gov. These sessions include Web‐based courses accessible from the physician’s own computer. Detailed information about the DATA 2000 paradigm and the physician waiver process also can be found on the SAMHSA Buprenorphine Web site. Additionally, information can be obtained by contacting the SAMHSA Buprenorphine Information Center by phone at 866‐BUP‐CSAT (866‐287‐2728) or by e‐mail at info@buprenorphine.samhsa.gov.

## Preparing for Office‐Based Opioid Treatment

Prior to embarking on the provision of office‐based addiction treatment services, medical practices that will be new to this type of care should undertake certain preparations to ensure the highest quality experience for patients, providers, and staff. Providers and practice staff should have an appropriate level of training, experience, and comfort with this new form of treatment. Linkages with other medical and mental health professionals should be established to ensure the availability of comprehensive community‐based treatment services.

### Physician Training, Experience, and Comfort Level

Physicians who intend to treat opioid addiction should seek to establish a level of comfort and expertise with this form of care. A physician’s comfort level in providing treatment for addiction will vary according to the physician and his or her practice situation. For example, a physician might choose to refer a patient with addiction and depression, depending on the severity of depression, whether a psychologist or psychiatrist is available in the area, and whether the patient can afford specialized mental health care, among other factors.

Expertise in treating opioid addiction includes knowledge of applicable practice standards or guidelines, familiarity with the evidence supporting the recommended treatments, protocols for primary treatment or referral of patients with certain complicating conditions (e.g., severe depression), and knowledge of any applicable regulations or laws. Physicians must become knowledgeable about the most up‐to‐date treatments for opioid addiction, including pharmacotherapy, psychosocial interventions, self‐help and mutual‐help groups, and other appropriate treatments. Physicians who treat opioid‐addicted patients with buprenorphine should participate in addiction medicine training and professional activities and should learn from other professionals in addiction treatment. Basic and ongoing training in addiction treatment will greatly enhance a physician’s effectiveness in treating opioid addiction.

Each patient presents with different and usually complex needs. Physicians who treat patients with opioid addiction in the office‐based setting must consider and plan for the full range of their patients’ needs before initiating treatment. Candidates for buprenorphine treatment of opioid addiction should be assessed for a broad array of biopsychosocial needs in addition to opioid use and addiction, and should be treated and/or referred for help in meeting those needs.

### Establishing Office Procedures

Before undertaking the provision of office‐based buprenorphine treatment, physicians should make arrangements to provide comprehensive care and contingency plans for patients who may not be appropriate candidates for this treatment. In addition, physicians should arrange for other physicians with DATA 2000 waivers to be available to provide care to the treating physician’s opioid addiction patients in the treating physician’s absence (e.g., while on vacation).

Office policies and procedures for opioid addiction treatment should be established, written, and clearly communicated to staff members and patients. Staff members should be trained and educated about opioid addiction, addiction treatment, patient confidentiality (see “Confidentiality and Privacy” section below), medication treatments, nonpharmacological treatments, behavioral characteristics of addiction, and the medical approach to addiction treatment.

Common behaviors and defense mechanisms of addicted patients should be anticipated. Medication must be stored in a secure location, and the possibility of diversion must be minimized. Office items (e.g., prescription pads, syringes, needles) and staff possessions should be secured to minimize theft.

### Establishing Treatment Linkages

Establishing linkages with other medical professionals is essential. Because patients addicted to opioids commonly have coexisting medical and psychiatric conditions, most physicians will need to establish linkages with other medical and mental health specialists, particularly those specializing in the evaluation and treatment of common comorbid conditions (e.g., hepatitis B and C, HIV, tuberculosis, mood disorders, anxiety disorders, personality disorders, risk of suicide and homicide). Physical examinations and laboratory evaluations will need to be completed either onsite or offsite from the office of the physician who provides office‐based buprenorphine treatment.

An up‐to‐date listing of community referral resources (e.g., therapy groups, support groups, residential therapeutic communities, sober‐living options) should be given to patients. Referral resource lists are available from the substance abuse agencies of some local and State governments. To maximize followthrough with referrals, it is most helpful if the physician has firsthand knowledge of these groups and programs. When referrals are made, compliance will increase if staff call to make appointments in the presence of patients. When making referrals to support groups, it is helpful to have an individual in the group who is willing to accompany the patient to his or her first meeting. Referrals to social workers and case managers are often beneficial in helping patients address legal, employment, and family issues.

### Summary

Figure 6-1 summarizes the policies, procedures, and items that should be established or arranged for in a medical practice prior to initiating office‐based opioid addiction treatment.

Figure 6-1. Policies, Procedures, and Items for Medical Practices To Establish Prior to Initiating Office‐Based Opioid Addiction Treatment

- Office policies and procedures for buprenorphine treatment
- Staff education and training
- Backup coverage for the practice
- Assurance of the privacy and confidentiality of addiction treatment information
- Linkages with qualified colleagues who will accept new referrals for buprenorphine treatment
- A referral network of medical specialists
- Timely physical examinations
- Linkages with medical treatment facilities, including opioid treatment programs
- A referral network of psychologists and psychiatrists with expertise in addictions, affective disorders, and chronic pain
- Linkages with addiction and psychiatric treatment programs
- Listing of community referral resources, including specific self‐help groups who would welcome buprenorphine patients (e.g., Self Management and Recovery Training [SMART] Recovery, Moderation Management)
- Online/Internet listings of self‐help groups (e.g., SMART Recovery, Moderation Management) that are accepting of individuals in recovery who are using medications as a part of that recovery

## Confidentiality and Privacy

Prior to initiating office‐based opioid addiction treatment, practice policies and procedures should be established that will guarantee the privacy and confidentiality of addiction treatment patients. Providers must comply with all applicable laws and regulations regarding the privacy and confidentiality of medical records in general, and of information pertaining to addiction treatment services in particular.

The privacy and confidentiality of individually identifiable information relating to patients receiving drug or alcohol treatment is protected by SAMHSA confidentiality regulation Title 42, Part 2 of the Code of Federal Regulations (42 C.F.R. Part 2). This regulation mandates that addiction treatment information in the possession of substance abuse treatment providers be handled with a greater degree of confidentiality than general medical information.

Occasionally, physicians will need to communicate with pharmacists and other healthcare providers about the addiction treatment of a particular patient (e.g., to verify a Suboxone® or Subutex® prescription). Regulation 42 C.F.R. Part 2 requires physicians providing opioid addiction treatment to obtain signed patient consent before disclosing individually identifiable addiction treatment information to any third party. A sample consent form with all the elements required by 42 C.F.R. Part 2 is included as appendix D. It is recommended that physicians have each new buprenorphine patient sign a copy of this form to prevent confidentiality problems at pharmacies when patients present with buprenorphine prescriptions. It is particularly important to obtain patient consent when telephoning or faxing prescriptions to pharmacies, as this information constitutes disclosure of the patient’s addiction treatment. When physicians directly transmit prescriptions to pharmacies, further redisclosure of patient‐identifying information by the pharmacy is prohibited, unless signed patient consent is obtained by the pharmacy. Regulation 42 C.F.R. Part 2 does not apply to pharmacies, however, when the patient delivers a buprenorphine prescription without telephone confirmation or other direct communication from a physician to the pharmacist.

The Health Insurance Portability and Accountability Act (HIPAA) of 1996, Public Law 104‐191 (see http://aspe.hhs.gov/admnsimp/pl104191.htm), which amends the Internal Revenue Service Code of 1986, mandates standardization of exchange formats for patient health, administrative, and financial data; requires development of unique identifiers for individuals, employers, health plans, and healthcare providers; and establishes security standards for protecting the confidentiality and integrity of individually identifiable health information. SAMHSA has prepared a document titled Comparison Between the Confidentiality of Alcohol and Substance Abuse Patient Records (42 C.F.R. Part 2) and the Health Insurance Portability and Accountability Act 1996. This document and a number of other HIPAA technical assistance tools are available on the SAMHSA HIPAA Web pages at http://www.hipaa.samhsa.gov/. See also the SAMHSA Treatment Assistance Publication (TAP) 13 Confidentiality of Patient Records for Alcohol and Other Drug Treatment (Lopez 1994), available on the SAMHSA Treatment Improvement Exchange Web site at http://www.treatment.org/taps/index.html. Additionally, the Subutex® and Suboxone® package labels (available on the FDA Web site at http://www.fda.gov/cder/drug/infopage/subutex_suboxone/default.htm) also contain information on Federal confidentiality rules and regulations. Physicians should also consult with their State medical authorities concerning privacy and confidentiality rules in their locales. Figure 6-2 lists some of the privacy and confidentiality issues that can arise in the course of addiction treatment.

Figure 6-2. Privacy and Confidentiality Issues in Addiction Treatment

- Information covered by the doctor/patient privilege
- Circumstances in which confidential information is protected from disclosure
- Exceptions to State laws protecting medical information
- Duty to report
- Communications with third parties (e.g., families, employers, allied health care providers, third party payers, law‐enforcement officers, responses to subpoenas)

## Buprenorphine Use in OTPs

On May 22, 2003, SAMHSA announced an interim final rule permitting OTPs serving individuals addicted to opioids to offer buprenorphine treatment along with methadone and levo‐alpha‐acetyl‐methadol (LAAM). The rule enables OTPs that are certified by SAMHSA to provide Subutex® and Suboxone® for opioid maintenance or detoxification treatment.

The provision of opioid addiction treatment with Subutex® and Suboxone® in SAMHSA‐certified OTPs does not require a DATA 2000 waiver. Additionally, such treatment is not subject to the 30‐patient limit that applies to individual physicians and group practices providing opioid addiction treatment outside the OTP system under the authority of a DATA 2000 waiver. The provision of opioid addiction treatment with Subutex® or Suboxone® in treatment settings other than OTPs, even by physicians who are licensed to work in OTPs, does require a DATA 2000 waiver and is subject to the 30‐patient limit for individual physicians and group practices.

OTPs providing Subutex® and Suboxone® for opioid maintenance or detoxification treatment must conform to the Federal opioid treatment standards set forth under 42 C.F.R. § 8.12. These regulations require that OTPs provide medical, counseling, drug abuse testing, and other services to patients admitted to treatment. To offer Subutex® and Suboxone®, OTPs need to modify their registration with the DEA to add Schedule III narcotics to their registration certificates. OTPs can initiate this streamlined process by fax or letter. The letter should include the OTP’s DEA registration number and request that the registration be amended to list Schedule III narcotic drugs. The letter must be signed by the program sponsor (program director) or medical director. Further information about this process can be found on the DEA Drug Registration Web site at http://www.deadiversion.usdoj.gov/drugreg/change_requests/sched_change.htm.