# Appendix J Field Reviewers

- Emizie Abbott, CCDC III
- Executive Director
- Cleveland Treatment Center, Inc.
- Cleveland, Ohio

- Patrick Abbott, M.D.
- Center on Alcoholism, Substance Abuse and Addiction
- Albuquerque, New Mexico

- Cynthia E. Aiken, M.S., LPA
- Executive Director
- Narcotic Drug Treatment Center, Inc.
- Anchorage, Alaska

- Doug Allen, M.S.W.
- Administrator
- Planning Policy and Legislative Relations
- Division of Alcohol and Substance Abuse
- Department of Social & Health Services
- State of Washington
- Olympia, Washington

- Leslie Amass, Ph.D.
- Principal Investigator
- Friends Research Institute, Inc.
- Los Angeles, California

- Robert E. Anderson
- Director, Research and Program Applications
- National Association of State Alcohol and Drug Abuse Directors
- Washington, District of Columbia

- Gerard Armstrong
- Deputy Director
- Managed Care/Health and Revenue Services
- Office of Alcoholism and Substance Abuse Services
- State of New York
- New York, New York

- Judith A. Arroyo, Ph.D.
- Coordinator
- Project COMBINE
- Center on Alcoholism, Substance Abuse and Addictions
- University of New Mexico
- Albuquerque, New Mexico

- Candace L. Baker, MAC, ACSW
- Director, Clinical Issues
- The National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia

- Doug Baker
- Head, Adult Services Branch
- Substance Abuse Services Section
- Division of Mental Health, Developmental Disabilities and Substance Abuse Services
- State of North Carolina
- Raleigh, North Carolina

- Roxanne Baker
- Director of Nor‐Cal NAMA
- Northern California National Alliance of Methadone Advocates
- Santa Cruz, California

- Steve Batki, M.D.
- Professor and Director of Research
- Department of Psychiatry
- Upstate Medical University
- Syracuse, New York

- Ann Belk
- Program Analyst
- Office of Diversion Control
- Drug Enforcement Administration
- Washington, District of Columbia

- Mark Beresky
- Secretary/Treasurer
- The Vermont Harm Reduction Coalition
- Co‐Director, The New England Chapter of the National Alliance of Methadone Advocates
- Putney, Vermont

- Bruce J. Berg, M.D.
- Vice President Medical Services
- Magellan Behavioral Health
- Bryn Mawr, Pennsylvania

- Robert Bick, M.A., SAC
- Director
- Champlain Drug and Alcohol Services
- Howard Center for Human Services
- Burlington, Vermont

- George Bigelow, Ph.D.
- Professor
- College on Problems of Drug Dependence
- Behavioral Pharmacology Research Unit
- Behavioral Biology Research Center
- Johns Hopkins Bayview Campus
- Baltimore, Maryland

- Anton C. Bizzell, M.D.
- Medical Officer
- Division of Pharmacologic Therapies
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Jack Blaine, M.D.
- Chief of Medications Research Grants Unit
- National Institute on Drug Abuse
- National Institutes of Health
- Bethesda, Maryland

- Linda Brady, Ph.D.
- Acting Chief of Molecular and Cellular Neuroscience Research Branch
- National Institute of Mental Health
- National Institutes of Health
- Bethesda, Maryland

- Judy Braslow
- Deputy Director for Policy
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Michael F. Brooks, D.O.
- Medical Director
- Saline Community Hospital
- Greenbrook Recovery Center
- Saline, Michigan

- Lawrence Brown, M.D., M.P.H.
- Senior Vice President
- Division of Medical Services Evaluation and Research
- Addiction Research Corporation
- Brooklyn, New York

- Andrew Byrne, M.D., B.S.
- Dependency Specialist, Medical Practitioner
- Redfern, New South Wales
- Australia

- Jim Callahan, Ph.D.
- Executive Vice President/Chief Executive Officer
- American Society of Addiction Medicine
- Chevy Chase, Maryland

- James C. Carleton, M.S.
- Director, Narcotic Treatment Programs
- CODAC Treatment Center, Inc.
- Providence, Rhode Island

- Louis Cataldie, M.D.
- Medical Director
- Office for Addictive Disorders
- Department of Health and Hospitals
- State of Louisiana
- Baton Rouge, Louisiana

- Susanne Caviness, Ph.D.
- Captain, U.S. Public Health Service
- Division of State and Community Assistance
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Richard Christensen, P.A., CAS
- Vice President and Director of Medical Services
- Community Medical Services
- Phoenix, Arizona

- Darrell Christian, Ph.D.
- Clinical Psychologist
- New Leaf Treatment Center
- Concord, California

- Barbara Cimaglio
- Administrator
- Office of Alcohol and Drug Abuse Programs
- Department of Human Services
- State of Oregon
- Salem, Oregon

- H. Westley Clark, M.D., J.D., M.P.H., CAS, FASAM
- Director
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Denise Clayborn, Ph.D.
- Human Services Adult and Opioid Replacement Consultant
- Office of Substance Abuse Services
- Department of Mental Health, Mental Retardation and Substance Abuse Services
- Commonwealth of Virginia
- Richmond, Virginia

- Edward J. Cone, Ph.D.
- Chief Executive Officer
- Conechem Research
- Severna Park, Maryland

- Michael Couty, M.A.
- Director
- Division of Alcohol and Drug Abuse
- Department of Mental Health
- State of Missouri
- Jefferson City, Missouri

- Michael J. Crookston, M.D.
- Psychiatrist, Chemical Dependency Services
- LDS Hospital
- Salt Lake City, Utah

- Denise Curry
- Chief of Liaison Unit
- Office of Diversion Control
- Drug Enforcement Administration
- Washington, District of Columbia

- Joy Davidoff
- Coordinator of Addiction Medicine
- Office of Alcoholism and Substance Abuse Services
- State of New York
- Albany, New York

- Peter A. DeMaria, Jr., M.D., FASAM
- Associate Professor of Psychiatry and Human Behavior
- Jefferson Medical College
- Thomas Jefferson University
- Philadelphia, Pennsylvania

- Doug DeShong
- Senior Product Manager, Suboxone
- Schering
- Kenilworth, Texas

- Pamela Detrick, Ph.D., ARNPC
- Assistant Professor
- School of Nursing
- University of Miami
- Miami, Florida

- Herman I. Diesenhaus, Ph.D.
- Buprenorphine Workgroup Coordinator
- Office of Evaluation, Scientific Analysis and Synthesis
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Alice Diorio
- President
- The Vermont Harm Reduction Coalition
- Co‐Director, The New England Chapter of the National Alliance of Methadone Advocates
- Putney, Vermont

- Martin C. Doot, M.D.
- Chief
- Division of Addiction Medicine
- Addiction Medicine/Family Practice
- Lutheran General Hospital Advocate
- Des Plaines, Illinois

- Alfonzo Dorsey
- Director of Quality Control
- Substance Abuse Treatment and Recovery
- Department of Social and Rehabilitative Services
- State of Kansas
- Topeka, Kansas

- Karen Downey, Ph.D.
- Assistant Professor
- Research Division on Substance Abuse
- Department of Psychiatry and Behavioral Neurosciences
- Wayne State University
- Detroit, Michigan

- Michael Duffy, R.N., CD
- Acting Assistant Secretary
- Office of Alcohol and Drug Abuse
- Department of Health and Hospitals
- State of Louisiana
- Baton Rouge, Louisiana

- Joel Egerston
- Special Assistant to the Director
- National Institute on Drug Abuse
- National Institutes of Health
- Bethesda, Maryland

- John P. Epling, M.D.
- 2303 Line Avenue
- Shreveport, Louisiana

- Virginia H. Ervin, B.S.N., CARN, COHN
- Utilization Review Case Manager
- Department of Alcohol and Other Drug Abuse Services
- State of South Carolina
- Columbia, South Carolina

- Garland S. Ferguson
- Director, Division of Treatment Services
- Bureau of Alcohol and Drug Abuse Prevention
- Department of Health
- State of Arkansas
- Freeway Medical Center
- Little Rock, Arkansas

- Michael Fingerhood, M.D.
- Associate Professor of Medicine
- Center for Chemical Dependence
- Johns Hopkins Bayview Medical Center
- Baltimore, Maryland

- Gary Fisher, Ph.D.
- Director and Professor
- Center for the Application of Substance Abuse Technologies
- University of Nevada, Reno
- Reno, Nevada

- Luceille Fleming
- Director
- Department of Alcohol and Drug Addiction Services
- State of Ohio
- Columbus, Ohio

- Paul Fudala, Ph.D.
- Clinical Toxicologist
- Philadelphia VA Medical Center
- Philadelphia, Pennsylvania

- Robert Fuller, M.D.
- Director
- Division of Clinical & Preventative Research
- National Institute on Alcohol Abuse and Alcoholism
- National Institutes of Health
- Rockville, Maryland

- George R. Gilbert, J.D.
- Director, Office of Policy Coordination and Planning
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Daniel J. Glatt, M.D., M.P.H.
- Fellow, Substance Abuse
- San Francisco VA Medical Center
- San Francisco, California

- William Glatt, M.D.
- Primary Care Physician
- Internal Medicine and Addiction Medicine
- South San Francisco, California

- Angel A. González, M.D.
- Senior Surgeon, U.S. Public Health Service
- Division of Pharmacologic Therapies
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Marc Gourevitch, M.D.
- Medical Director
- Division of Substance Abuse
- Albert Einstein College of Medicine
- Yeshiva University
- Bronx, New York

- Prakash L. Grover, Ph.D., M.P.H.
- Senior Science Advisor
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Jack Gustafson
- Executive Director
- National Association of State Alcohol and Drug Abuse Directors
- Washington, District of Columbia

- Susan W. Haikalis, LCSW
- Director
- HIV Services and Treatment Support
- San Francisco AIDS Foundation
- San Francisco, California

- William F. Haning III, M.D., FASAM
- Associate Dean
- John A. Burns School of Medicine
- University of Hawaii
- Honolulu, Hawaii

- Michael Harle
- President/Executive Director
- Gaudenzia, Inc.
- Norristown, Pennsylvania

- Dana Harlow, LISW, CCDC III‐E
- Manager
- Department of Alcohol and Drug Addiction Services
- State of Ohio
- Columbus, Ohio

- Reva Harris, M.B.A., B.S.
- Fellow
- Office of Congressman Charles Rangel
- Washington, District of Columbia

- John Harsany, Jr., M.D.
- Medical Director
- Riverside County Substance Abuse Program
- Hemet, California

- Dory Hector
- State Methadone Authority
- Division of Substance Abuse Services
- Department of Mental Health and Mental Retardation
- State of Alabama
- Montgomery, Alabama

- Renata J. Henry
- Director
- Division of Alcoholism, Drug Abuse, and Mental Health
- Department of Health and Social Services
- State of Delaware
- New Castle, Delaware

- James Herrera, M.A., NCC, LPCC
- Senior Counselor
- Center on Alcoholism, Substance Abuse, and Addictions
- University of New Mexico
- Albuquerque, New Mexico

- Edward J. Higgins, M.A.
- Executive Director
- Jersey Shore Addiction Services, Inc.
- Asbury Park, New Jersey

- John Hopper, M.D.
- Medical Director
- UPC Opiate Dependence Treatment
- Detroit, Michigan

- Elizabeth F. Howell, M.D.
- Senior Medical Editor
- Atlanta, Georgia

- Ronald J. Hunsicker, D.Min., FACATA
- President/Chief Executive Officer
- National Association of Addiction Treatment Providers
- Lititz, Pennsylvania

- Ray Hylton, M.S.N., R.N.
- Division of Pharmacologic Therapies
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Jerome Jaffe, M.D.
- Clinical Professor of Psychiatry
- University of Maryland
- Towson, Maryland

- Donald R. Jasinski, M.D.
- Chief
- Center for Chemical Dependence
- Johns Hopkins Bayview Medical Center
- Baltimore, Maryland

- Kimberly Johnson
- Director
- Office of Substance Abuse
- State of Maine
- Augusta, Maine

- Rolley E. Johnson, Pharm.D.
- Associate Professor
- Department of Psychiatry and Behavioral Sciences
- Behavioral Pharmacology Research Unit
- Johns Hopkins University School of Medicine
- Baltimore, Maryland

- Linda R. Wolf Jones, D.S.W.
- Executive Director
- Therapeutic Communities of America
- Washington, District of Columbia

- Herman Joseph, Ph.D.
- Research Scientist
- Office of Alcoholism and Substance Abuse Services
- State of New York
- New York, New York

- George Kanuck
- Public Health Analyst
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Janice F. Kauffman, M.P.H., R.N., CAS
- Director, Substance Abuse Treatment Services
- North Charles, Inc.
- Director, Addiction Psychiatry Service
- Brigham and Women’s Hospital
- Assistant Professor of Psychiatry
- Harvard Medical School
- Somerville, Massachusetts

- Chris Kelly
- President, DC‐Chapter
- Advocates for Recovery Through Medicine
- Washington, District of Columbia

- Maureen Kerrigan, J.D.
- Policy and Legislative Analyst
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Amesbury, Massachusetts

- Steven Kipnis, M.D., FACP
- Medical Director
- Blaisdell Addiction Treatment Center
- Orangeburg, New York

- Monika Koch, M.D.
- Addiction Psychiatrist
- Friends Research Associates
- Berkeley, California

- Thomas R. Kosten, M.D.
- Professor
- Department of Psychiatry
- Yale University
- American Academy of Addiction Psychiatry
- VA Connecticut Healthcare System
- West Haven, Connecticut

- Ottis L. Layne, M.D.
- Medical Director
- Emergency Department
- Hill County Memorial Hospital
- Fredericksburg, Texas

- Ira Lubell, M.D., M.P.M.
- Medical Director
- Santa Clara Valley Medical Center
- San Jose, California

- Robert Lubran, M.S., M.P.A.
- Director
- Division of Pharmacologic Therapies
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- James W. Luckey, Ph.D.
- Associate Director
- Substance Abuse Research Group
- Westat
- Rockville, Maryland

- Stephen Magura, Ph.D., CSW
- Director
- Institute for Treatment and Services Research
- National Development and Research Institutes
- New York, New York

- Kathleen Masis, M.D.
- Medical Officer for Chemical Dependency
- Office of Health Care
- Billings Area Indian Health Service
- U.S. Department of Health and
- Human Services
- Billings, Montana

- Stephen S. Mason
- Director
- Office of Behavioral Health Services
- Division of Alcoholism and Drug Abuse
- Department of Health and Human Resources
- State of West Virginia
- Charleston, West Virginia

- Mary Mayhew
- Congressional Division
- National Institute on Drug Abuse
- National Institutes of Health
- Bethesda, Maryland

- Philip S. McCullough
- Director
- Bureau of Substance Abuse Services
- Division of Supportive Living
- Department of Health and Family Services
- State of Wisconsin
- Madison, Wisconsin

- John J. McGovern, CSW
- Director
- Clinical Services
- HELP/Project Samaritan, Inc.
- Bronx, New York

- Kathleen McGowan, J.D.
- Legislative Assistant
- Office of Senator Moynihan
- Washington, District of Columbia

- Paul McLaughlin
- Executive Director
- Hartford Dispensary
- Hartford, Connecticut

- John Mendelson, M.D.
- Associate Clinical Professor
- Psychiatry and Medicine
- Drug Dependence Research Center
- University of California at San Francisco
- San Francisco, California

- Robert Miller, M.A.
- Operations Manager
- Office of Alcohol and Drug Abuse Programs
- Department of Human Services
- State of Oregon
- Salem, Oregon

- Sharon Morello, R.N., B.S.N.
- Nursing Care Evaluator
- Division of Substance Abuse
- Department of Mental Health, Retardation and Hospitals
- State of Rhode Island
- Cranston, Rhode Island

- Don Myers
- Treatment Field Manager/State Methadone Authority
- Alcohol and Drug Abuse Division
- Department of Human Services
- State of Colorado
- Denver, Colorado

- David K. Nace, M.D.
- Senior Vice President
- United Behavioral Health
- Philadelphia, Pennsylvania

- Madeline A. Naegle, Ph.D., R.N., C.S., FAAN
- Associate Professor
- Division of Nursing
- School of Education
- New York University
- New York, New York

- Susan F. Neshin, M.D.
- Medical Director
- Jersey Shore Addiction Service, Inc.
- Asbury Park, New Jersey

- Thomas Nicholson, Ph.D., M.P.H., M.A.Ed.
- Professor
- Department of Public Health
- Western Kentucky University
- Bowling Green, Kentucky

- Edward V. Nunes, M.D.
- Research Psychiatrist and Assistant Professor of Clinical Psychiatry
- New York State Psychiatric Institute
- New York, New York

- David Ockert, D.S.W.
- Executive Director
- Parallax Center
- New York, New York

- Kerry O’Neil
- Chief of Treatment Services
- Division of Substance Abuse
- Department of Mental Health, Retardation and Hospitals
- State of Rhode Island
- Cranston, Rhode Island

- Patricia Isbell Ordorica, M.D.
- James A. Haley Veterans’ Hospital
- Tampa, Florida

- Mark Parrino, M.P.A.
- President
- American Methadone Treatment Association
- New York City, New York

- David Pating, M.D.
- Medical Director
- Chemical Dependency Recovery Program
- Kaiser San Francisco
- San Francisco, California

- J. Thomas Payte, M.D.
- Medical Director
- Drug Dependence Associates
- San Antonio, Texas

- Lillian Pickup
- Administrator
- Department of Alcoholism and Substance Abuse
- State of Illinois
- Chicago, Illinois

- Deborah Powers
- State Methadone Authority
- Bureau of Substance Abuse Services
- State of Wisconsin
- Madison, Wisconsin

- Sandi Record
- Director
- Treatment, Prevention and Program Department
- Office for Addiction Disorder, Alcohol and Drug Abuse
- State of Louisiana
- Baton Rouge, Louisiana

- Nicholas Reuter, M.P.H.
- Division of Pharmacologic Therapies
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Michael Rizzi
- Deputy Director
- CODAC Treatment Centers
- Cranston, Rhode Island

- Diedre Roach, M.D.
- Administrator
- Alcohol Prevention and Recovery
- Administration
- District of Columbia Department of Health
- Washington, District of Columbia

- Barbara T. Roberts, Ph.D.
- Policy Analyst
- White House Office of National Drug Control Policy
- Washington, District of Columbia

- June Ross, B.S., ICADC
- Executive Director
- 12 12, Inc.
- Tulsa, Oklahoma

- Pedro Ruiz, M.D.
- Mental Sciences Institute
- University of Texas
- Houston, Texas

- Richard Saitz, M.D., M.P.H.
- Associate Professor of Medicine
- Clinical Addiction Research and Education (CARE) Unit
- Section of General Internal Medicine
- Boston Medical Center and Boston University School of Medicine
- Boston, Massachusetts

- Jeff Samet, M.D., M.A., M.P.H.
- Associate Professor
- Boston University School of Medicine
- Boston, Massachusetts

- Sidney Schnoll, M.D., Ph.D.
- Professor and Chairman
- Addiction Medicine
- Medical College of Virginia
- Virginia Commonwealth University
- Richmond, Virginia

- Mary Schumacher
- Director
- Behavioral Health Services Division
- Department of Health
- State of New Mexico
- Santa Fe, New Mexico

- Ian A. Shaffer, M.D.
- Principal
- Ian A. Shaffer & Associates, L.L.C.
- Reston, Virginia

- Steve Shoptow, Ph.D.
- Integrated Substance Abuse Programs
- University of California at Los Angeles
- Los Angeles, California

- Larry Siegel, M.D.
- Senior Deputy Director
- Administrator
- Addiction Prevention and Recovery Administration
- District of Columbia Department of Health
- Washington, District of Columbia

- Cynthia L. Spencer, D.O.
- Medical Director
- Substance Abuse Services
- Lansing, Michigan

- George Stavros, M.D.
- Medical Director
- Community Medical Services
- Phoenix, Arizona

- Richard T. Suchinsky, M.D.
- Associate Chief for Addictive Disorders
- Mental Health and Behavioral Sciences Service
- U.S. Department of Veteran Affairs
- Washington, District of Columbia

- Kenneth Sunamoto, M.D.
- Medical Director
- Drug Addiction Services of Hawaii, Inc.
- Honolulu, Hawaii

- Karen Tannert, R.Ph.
- Chief Pharmacist
- Drugs and Medical Devices Division
- Department of Health
- State of Texas
- Austin, Texas

- Tony Tommasello, Ph.D.
- Department of Pharmacy Practice and Science
- University of Maryland School of Pharmacy
- Baltimore, Maryland

- Alan Trachtenberg, M.D.
- Medical Director
- Division of Pharmacologic Therapies
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Donald Weinbaum
- Coordinator
- Criminal Justice and Block Grant Planning Unit
- Division of Addiction Services
- Department of Health
- State of New Jersey
- Trenton, New Jersey

- Richard Weisskopf
- Manager
- Methadone Treatment Services
- Office of Alcoholism and Substance Abuse
- Department of Human Services
- State of Illinois
- Chicago, Illinois

- Donald R. Wesson, M.D.
- Consultant, CNS Medications Development
- Oakland, California

- Charles L. Whitfield, M.D.
- Private Practice of Addiction Medicine
- Atlanta, Georgia

- Cheryl Williams
- Director
- Division of Drug and Alcohol Program Licensure
- Department of Health
- State of Pennsylvania
- Harrisburg, Pennsylvania

- Jaslene Williams
- Assistant Director
- Division of Mental Health
- U.S. Virgin Islands
- Christiansted, Virgin Islands

- Janet Wood
- Director
- Alcohol and Drug Abuse Division
- Department of Human Services
- State of Colorado
- Denver, Colorado

- William Wood, M.D.
- Chief Medical Officer
- ValueOptions
- Falls Church, Virginia

- George E. Woody, M.D.
- Professor
- Department of Psychiatry
- Treatment Research Institute
- Philadelphia, Pennsylvania

- Richard Yoast, Ph.D.
- Director
- Office of Alcohol
- American Medical Association
- Chicago, Illinois

- Leah Young
- Public Affairs Specialist
- Office of Communication and External Liaison
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Edward Zborower
- Program Representative/State Methadone Authority
- Bureau of Substance Abuse and General Mental Health
- Department of Health Services
- State of Arizona
- Phoenix, Arizona

- Steve Zukin
- Division of Treatment Research and Development
- National Institute on Drug Abuse
- National Institutes of Health
- Bethesda, Maryland